# Appendixes

Appendix A Exact Search Strings

Appendix B Sample Data Abstract Forms

Appendix C Excluded Studies

Appendix D Ongoing Research

Appendix E Peer Reviewers

Appendix F Maternal-Fetal Surgical Procedures: Background and Context