# Maternal-Fetal Surgical Procedures: Background and Context

## Overview

The purpose of the Maternal-Fetal Surgical Procedures report is to describe the current state of research and practice of maternal-fetal surgical procedures; the report does not offer guidance on whether or when such procedures are appropriate. Congenital abnormalities that can be repaired prenatally occur in a small percentage of full-term births, and because of advances in imaging techniques such as ultrasound, many more congenital abnormalities are being diagnosed in utero. As these abnormalities are more frequently recognized prior to delivery, maternal-fetal surgical procedures have emerged as a potential option for treating some of these defects. Substantial questions remain about both the safety and efficacy of fetal surgical corrections. In some cases, the natural history of the conditions is poorly understood, making comparisons to no treatment or postnatal intervention difficult.

In addition, comparisons of fetal versus postnatal surgery must consider the safety of the mother, yet limited comparative data exist. The issue is particularly complicated because while congenital defects are relatively common in aggregate, individual congenital abnormalities occur infrequently, making effective study very difficult. Ongoing trials are evaluating some of the most common fetal surgeries (Appendix D).

Therefore, there is substantial uncertainty about maternal-fetal surgical procedures for patients and their physicians in choosing a course of treatment as well as for stakeholders making coverage decisions. In order to reduce this uncertainty, it is helpful to describe the full scope of comparative outcome evidence for in utero precedures and conventional postnatal (neonatal) interventions. It is of particular importance to weigh benefits against harms of interventions because harms associated with fetal surgery vary with the level of invasiveness and pose risks to the health of the fetus and mother. Risks may include bleeding, infection, preterm labor, complications associated with anesthesia medications, prolonged hospitalization, and threatened maternal reproductive future. The overriding concern in any fetal operation must be maternal and fetal safety. Secondary goals include avoiding preterm labor and accomplishing the goals of the procedure for the fetus.

Maternal-fetal surgical procedures began with transfusions for hemolytic diseases in the 1960s,1 but the field accelerated in the 1980s with advances in ultrasonography that allowed visualization of the fetus for surgical intervention–as well as earlier diagnosis of abnormalities.2 In a 40-year time span, fetal procedures have moved from transfusion-focused work to open surgical repair of conditions such as obstructive uropathy, and is increasingly being done with minimally invasive approaches.3 Although postnatal intervention is best for most fetal abnormalities (particularly in light of risks associated with in utero surgeries), for a few conditions, the fetus’s condition can deteriorate so rapidly in the womb as to make early intervention necessary to avoid either death or substantially higher morbidity after birth.

Open surgery on the fetus was first done in 1981 for obstructive uropathy by Dr. Michael Harrison at the University of California, San Francisco (UCSF),2,4 and endoscopic approaches have since evolved from largely diagnostic procedures to therapeutic modality over the last 30 years. Soon after the first open procedures, the International Fetal Medicine and Surgery Society (IFMSS) was founded to carefully support growth of the field through the sharing of data, a registry of cases, and evolving principles for when fetal surgery should be considered. The IFMSS emphasized the need for research transparency through publishing in the peer-reviewed literature. In addition, this group established a set of principles recommended to guide fetal interventions:5

- The disorder should be significant
- The natural history (and postrepair development) should be known
- There is inadequate postnatal therapy
- Maternal risks are minor and acceptable
- An animal model exists for defect and procedure
- The defect is an isolated one for which there is a complete and accurate diagnosis
- There is superb parental counseling
- A multidisciplinary team is in agreement regarding the treatment plan
- Patients have access to high-level medical, bioethical, and psychosocial care

The field of maternal-fetal surgery has evolved tremendously. Some approaches are still in the experimental stage, while others have substantially more research or are being increasingly accepted as standard practice. The time is right to assess the status of surgical intervention on the fetus for those conditions most commonly treated in this way. Therefore, the goal of the brief is to describe the current state of literature and practice of maternal-fetal surgical procedures for several congenital abnormalities ranked of high importance by stakeholders:

- Sacrococcygeal teratoma
- Congenital diaphragmatic hernia
- Thoracic lesions: congenital cystic adenomatoid malformation and bronchopulmonary sequestration
- Obstructive uropathy
- Myelomeningocele
- Twin-twin transfusion syndrome
- Cardiac malformations

## Key Questions Addressed in This Appendix

The key questions for this brief that are addressed in this appendix were as follows:

### Key Question 1

a. What fetal diagnoses are currently treatable with a maternal-fetal surgical procedure? For each fetal diagnosis that is potentially treatable with a maternal-fetal surgical procedure, what is the annual number of fetuses that could potentially benefit from the procedure?
b. What maternal-fetal surgical procedures are done in the United States? What is an estimate of the number of hospitals that perform each procedure and utilization of each procedure?
c. For each fetal diagnosis, which procedures or techniques are used?
d. For each maternal-fetal surgical procedure, what anesthesia is used? What are the potential harms to the fetus and mother from the anesthesia?
e. For each fetal diagnosis, what are the alternatives? For each fetal diagnosis, what are the theoretical advantages and disadvantages (including potential safety issues and harms to both the mother and fetus) of maternal-fetal surgical procedures relative to the alternatives?
f. What training programs exist for maternal-fetal surgical procedures? What special requirements are needed in hospitals that perform fetal surgical procedures?

In addition, a systematic scan of the research literature is presented in the full report.

## Overview of Methods

### Search for Current Practice and Research Data

We searched the Internet extensively to identify locations in the United States offering maternal-fetal surgical procedures and verified identified sites with our key informants. Three primary Web sites contributed the bulk of the information: www.naftnet.orgwww.naftnet.org; www.fetalhope.orgwww.fetalhope.org; and www.tttsfoundation.orgwww.tttsfoundation.org. In addition, we searched Lexis Nexis and Proquest for lay articles on maternal-fetal surgical procedures that might point to locations from which we could gather additional practice information (final search 2/6/09). For these searches, we used the terms “fetal surgery” and “in utero surgery” as well as searched individually for each of the conditions being examined in this brief. For information on insurers’ practices, we selected a set of insurers and used the Internet to search for their online coverage policies. Once identified, they were catalogued in a database and printed out for filing with the date of access. To identify current research, we searched Clinicaltrials.gov (clinicaltrials.gov) and the National Institutes of Health Reporter databases (http://projectreporter.nih.gov), and we worked with experts to identify any additional research we might have missed.

### Expert Discussions

We consulted with experts selected because of their expertise in the following areas: expertise in each of the conditions of interest, those who could offer historical perspective on maternal-fetal surgical procedures, and individuals who had a particular subspecialty expertise, such as ethics. These three expert panels included 17 individuals, with whom we held conversations via phone lasting from 20 to 45 minutes. The conversations were unstructured and intended to elicit context and background related in particular to current practice of maternal-fetal surgery.

### Results Regarding Current Practices

Our description of the current practice of maternal-fetal surgical procedures is limited to the United States and is derived from a combination of approaches, including internet sources and key informant discussions.

Geographic distribution and structure of maternal-fetal centers. There is no system of accreditation or certification that would make identifying all practitioners of maternal-fetal surgical procedures straightforward. As with all emerging technologies, there is a tendency for excitement generated around their potential to precipitate their adoption into practice, sometimes in the absence of strong, comparative research, but with the hope of helping infants with poor prognoses. Certain surgical procedures are farther along in their evolution and therefore are relatively more common than others, in particular, use of shunts for obstructive uropathy (OU) and laser ablation for twin-twin transfusion syndrome (TTTS).

We attempted to identify as many locations currently providing the maternal-fetal surgeries as possible in this brief (Table 1); however, that number and those locations are a rapidly evolving group, and therefore, these data may quickly become out of date. A starting point for identifying centers providing maternal-fetal therapy is the North American Fetal Therapy Network (NAFTnet) (www.naftnet.org). This network is a voluntary association of centers in the United States and Canada that perform advanced in utero techniques (including surgical ones). A similar network exists in Europe and is called Eurofoetus. These centers have agreed to work cooperatively to advance the practice of in utero therapies, including sharing data and providing educational resources for patients. A number of the centers conducting the highest volume of in utero surgical procedures are members of NAFTnet, with some notable exceptions. For example, the USFetus group performs a number of laparoscopic procedures in utero. In addition, we searched the internet and queried experts about who they knew to be using these surgical approaches. Through a combination of methods, we snowballed the list in Table 1. Of note, our goal was to identify centers that provide services to patients beyond experimental attempts and that therefore would be clinically available to U.S. patients. It should be noted that several key informants indicated concern that interventions for TTTS with laser, and for OU with shunting were proliferating perhaps too rapidly without oversight. However, we were unable to identify many sites claiming to offer in utero treatment for OU.

Table 1 Clinical centers offering maternal-fetal surgical procedures by condition and NAFTnet affiliation

Clinical affiliation | Affiliated hospital | NAFTnet Affiliate | Sacrococcygeal teratoma | Congenital diaphragmatic hernia (CDH) | Thoracic lesions | Obstructive uropathy | Myelomeningocele (spina bifida) | Twin-twin transfusion syndrome (TTTS) | Cardiac malformations
Baltimore, MD University of MD Center for Advanced Fetal Care | University of Maryland Medical Center/University Hospital | √ | | | | | | √
Boston, MA Brigham and Women’s Hospital/Children’s Hospital Advanced Fetal Care | Massachusetts General Hospital/Children’s Hospital Boston | √ | √ | √ | √ | √ | | √ | √
Chapel Hill, NC UNC Maternal Fetal Medicine | Rex Hospital | √ | | | | | | √
Cincinnati, OH Fetal Care Center of Cincinnati | Cincinnati Children’s Hospital/Good Samaritan Hospital/University Hospital | √ | √ | √ | √ | √ | | √
Columbus, OH Ohio State University | Ohio State University Medical Center/Nationwide Children’s Hospital | √ | | | | √ | | √
Dallas, TX Southwestern Medical Center | UT Southwestern University Hospital/Parkland Memorial Hospital | √ | | | √ | √
Detroit, MI^*^ Wayne State University | Hutzel Women’s Hospital | √
Houston, TX Baylor: Texas Children’s Fetal Center | Texas Children’s Hospital/St. Luke’s Episcopal Hospital | √ | √ | √ | √ | √ | | √
Los Angeles, CA Institute for Maternal Fetal Health, University of Southern California | Hollywood Presbyterian Medical Center/Children’s Hospital Los Angeles | | √ | √ | √ | √ | | √ | √
Milwaukee, WI International Institute for Treatment of TTTS | Wheaton-Franciscan Healthcare/St. Joseph Regional Medical Center | | | | | | | √
Miami, FL University of Miami | Jackson Memorial Hospital | | √ | √ | √ | √ | | √ | √
Minneapolis, MN Minnesota Perinatal Physicians | Abbott Northwestern Hospital | | | | | | | √
Nashville, TN Junior League Center for Advanced Maternal- Fetal Care | Monroe Carell Jr. Children’s Hospital/Vanderbilt University Medical Center | √ | | | √ | √
New Haven, CT^*^ Yale University Medical Center | Yale-New Haven Hospital | √
New York, NY Columbia University Medical Center | New York Presbyterian Hospital/Sloane Hospital for Women | √ | | | | √
Philadelphia, PA The Center for Fetal Diagnosis and Treatment | The Children’s Hospital of Philadelphia | √ | √ | √ | √ | √ | √ | √
Phoenix, AZ Phoenix Perinatal Associates | Arrowhead Hospital/Phoenix Children’s Hospital | √ | | | | | | √
Pittsburgh, PA * Magee-Women’s Hospital of the University of Pittsburgh Medical Center | University of Pittsburgh Medical Center | √
Providence, RI The Brown Fetal Treatment Program | Hasbro Children’s Hospital/Women and Infants’ Hospital of Rhode Island | √ | | √ | √ | √ | | √
Salt Lake City, UT Maternal-Fetal Services of Utah | St. Mark’s Hospital | | | | | √ | | √
San Diego, CA UCSD Fetal Surgery Program | UCSD Medical Center | | | | | | | √
San Francisco, CA UCSF Fetal Treatment Center | UCSF Children’s Hospital | √ | √ | √ | √ | √ | √ | √
Seattle, WA Evergreen Healthcare | Evergreen Hospital/Eastside Maternal Fetal Medicine at Overlake Hospital Medical Center | √ | | | √ | √ | | √

* information on procedures offered not publicly available

Models of care. Although a range of modes of care exist, inevitably, maternal-fetal procedures require a team of physicians and staff who are knowledgeable and experienced at working together. Programs may be led primarily either by pediatric surgeons or by obstetricians or may be a collaborative effort between the two specialties in which the obstetrician gains access to the uterus and/or fetus and the pediatric surgeon does the repair. Table 2 presents examples of selected models of care currently in practice; this taxonomy is adapted from Harrison.6 These examples are not exclusive or prescriptive; they are simply examples.

Table 2 Selected models of maternal-fetal surgical centers

Model | Description
Academic multidisciplinary | Academic multidisciplinary model with a large team reflecting expertise in perinatology, neonatology, pediatric surgical subspecialties, genetics, prenatal diagnosis, and anesthesia. Developed by pediatric surgeons and includes active participation of a large multidisciplinary conference and strong collaboration with basic sciences and animal research. Provides treatment for a range of conditions and may be led by a pediatric surgeon or maternal fetal medicine (MFM) specialist or both.
Export | Centralized care that travels to the patient; 2 physicians travel with fetoscopic equipment to other network hospitals to perform surgeries; may also train physicians and staff in those centers. In a system as large as Hospital Corporation of America (HCA), the need for availability of services, particularly for the more common conditions such as TTTS, is likely to increase. Rather than having many trained physicians at HCA hospitals, HCA opted to have a surgical team in one location that would go to the hospital where the patient was rather than having the patient come to them. Therefore, they export the program to other sites as needed. In addition, they have offered to participate in the establishment of centers at academic sites in several locations.
Perinatologist-led | MFM specialist alone or with other surgeons as needed (e.g., MFM specialist alone for laser ablation or with a neurosurgeon for myelomeningocele repair). Sometimes uses a “handoff” model where the obstetrician (OB) accesses the uterus, a different surgeon does the repair, and then the OB closes as per usual in cesarean section. In one example, the team includes 1 senior and 1 junior MFM specialist, and 1 senior and 1 junior pediatric surgeon. At least one of the senior physicians must be at each procedure.
Super specialist | An individual or group focuses on developing expertise in treating one condition in particular, or in using one approach. This can serve to centralize expertise.

Fetal surgery centers often also include the role of a “fetal board” or other conference that comprises a multidisciplinary group of individuals who meet regularly to discuss potential cases and review past cases. This approach has been described in the literature6–8 and can be helpful in protecting the surgical team, who may have perceived gain (e.g., opportunity for an exciting procedure, increase in knowledge and scientific discovery, prestige from developing new techniques) from being perceived as the sole decisionmaker or source of information about the procedure’s appropriateness. It is also an important opportunity to share experiences and to put in place mechanisms for tracking outcomes and processes both prospectively and retrospectively. This multidisciplinary approach has been evaluated8 and supported as an appropriate model.3

Training to conduct maternal-fetal surgical procedures. No licensing or accreditation group oversees maternal-fetal surgical procedures and credentialing. Indeed, it is difficult to determine what governing group would oversee the training of a subspecialty that includes individuals from diverse medical specialties. Given the learning curve associated with any of these surgical approaches, several experts expressed concern over the practice of traveling to Europe to attend a number of cases over what may be a short period of time (up to several weeks) as the extent of training.9 Absent traveling to Europe, there are two primary models of training in the United States: (1) in-house training in which experienced physicians invite other physicians to learn from them and (2) exported training in which experienced groups travel to other centers to train physicians and staff in their own environment and help them to establish the capacity for maternal-fetal surgical procedures.

The first approach (in-house) can either be established as a formal fellowship or as an “apprenticeship” that may serve as a precursor to having an individual physician join a given team. For example, as the site of the earliest open fetal surgeries, University of California San Francisco (UCSF) has provided training for a number of physicians who have gone on to develop programs at other sites (e.g., Children’s Hospital of Philadelphia, Fetal Care Center of Cincinnati). Physicians at several sites reiterated their openness to having fellow physicians join them to learn surgical procedure.

Three sites currently offer a fellowship: CHOP, Baylor College of Medicine–Texas Children’s Fetal Center, and the Fetal Care Center of Cincinnati. To date, the fellowship at CHOP has produced three “certified fellows.” Cincinnati has had three fellows since 2006, and faculty at Baylor are training their first fellow. Therefore, opportunities to obtain formal fellowship training are exceedingly rare, and the potential need for expanding opportunities has now been raised in the literature.9 At both existing fellowships, significant emphasis is placed on the need to observe and understand cases, the selection of appropriate cases for intervention, and the counseling process for families. At CHOP, successful fellows are prepared to do laser ablation for TTTS or place shunts for OU; neither fellowship purports to produce “graduates” immediately prepared to conduct open fetal surgical procedures. CHOP is also home to the only NICHD-funded training grant (T32) in fetal biology and therapy, which provides strong integration of the clinical practice with research.

In the second model, established centers train physicians at other sites and/or help them to establish their program. Training may take place at the original center’s site or at the learning center’s site. For example, Cincinnati Children’s Hospital has agreements in place to offer training in laser coagulation at four sites to selected maternal-fetal specialists with extensive experience in prenatal diagnosis and treatment. These specialists have not yet had the opportunity to learn fetoscopic techniques and invest up to 2 years in training before taking on their own cases. The agreements include an understanding that individuals at the extant sites will come to Cincinnati for training, then faculty from Cincinnati will go to the extant sites to supervise, and finally, that early in their practice, the extant sites will only attempt the procedure on the simpler case in which the placenta is posterior.

A third training model has been proposed in which telemedicine could be used to train and supervise laser coagulation, even internationally,10–11 but issues of insurance liability and other logistics continue to be clarified. Finally, both informants and the literature stress the importance of integrating animal research with practice, both for training and practice purposes. In addition to furthering knowledge and techniques in the field, animal research is a practical way to develop and maintain surgical skills, particularly in the case of low-volume conditions. Some maternal-fetal medicine sites, particularly at academic centers, have ongoing animal research integrated into their programs, and some use these facilities for surgical training. A number of the papers reviewed in the literature review also described development and practice of techniques in the animal lab, with an eye toward describing the numbers of cases necessary to achieve proficiency before moving to human study and practice.12–14

Access to clinical care and research. A particular issue garnering discussion is the question of whether maternal-fetal procedures should be regionalized in “centers of excellence.”9 Evidence is strong that surgical skill improves with volume; for example, estimates of the number of cases needed to achieve proficiency in laser coagulation in TTTS range from 50^10^ to 75,^15^ with 20^15^ per year suggested to maintain proficiency. Even with the most common conditions that are treatable in utero, the number of cases per year is likely to be low across the United States. Therefore, those cases centralized with surgical teams who would be most practiced, could theoretically provide the best care.9 The two most common of the candidate conditions for in utero repair (TTTS and myelomeningocele) present interesting examples.

In the case of myelomeningocele, prenatal treatment is limited to the Management of Myelomeningocele (MOMS) trial, currently being conducted at three sites (UCSF, CHOP, and Vanderbilt Medical Center). Even with a national agreement not to provide surgical repair outside of the trial, obtaining adequate numbers has been challenging, suggesting that if the treatment were available in more sites, adequate numbers to develop or maintain proficiency would be very difficult to achieve. Enrollment in the trial may have been affected by a drop in the number of U.S. cases, potentially resulting from the introduction of folate supplementation as well as the limited number of centers participating in the study, which may make patients reluctant to participate given that patients randomized to in utero treatment are required to stay at the fetal center for the duration of their pregnancy (potentially 2–3 months).

In the case of TTTS, several experts expressed concern that in utero treatment, specifically laser ablation, was proliferating too rapidly and with little oversight related either to training or practice—a particular concern in light of the learning curve described above. However, empirical evidence to this effect does not exist, so this idea is opinion only. Concerns about the rapidly expanding volume rest on expert opinion and analogies to other surgical fields.

There seems to be some support for regionalization of care, but we did not identify specific suggestions as to how the regional centers might be designated beyond the selection by insurers of centers of excellence where they might require that their insured population seek care. The number of centers necessary depends by condition on the prevalence of cases that are appropriate for intervention and should be determined with consideration of the number of cases needed to develop and maintain surgical proficiency, or other considerations including neonatal intensive care unit (NICU) level and other resource availability. These are metrics that are only beginning to be addressed in the literature, and only for the more common conditions. Conversely, regionalization of care could inhibit access for patients unable to travel, either for medical, financial, or logistical reasons. It should be noted that traveling to obtain in utero therapy most often includes a necessary hotel stay as surgeons prefer that patients remain close by for some period after surgery, even up to delivery. The export model described above is an attempt to mitigate these issues and increase access while keeping services within one system.

The question of distribution of and access to maternal-fetal surgical procedures is integrally connected to payment systems, specifically whether a given technique is in the realm of nonfunded early innovation, funded research, or reimbursed medical care. Early innovation most often takes place in academic medical centers as one time attempts to intervene in a grim clinical prognosis—enthusiasm spreads as surgeons share their experience before a study is necessarily developed. Academic centers may have the means to support innovation; however, for a medical practice to become available to many people, research must be strong enough to demonstrate benefit. An example is that of open surgery to repair myelomeningocele, which was gaining popularity before adequate research was conducted when concerns were raised about high rates of morbidity. The National Institutes of Health is sponsoring a randomized controlled trial (RCT), and all U.S. centers have agreed to a moratorium in the U.S. as part of which the surgery is only offered in the context of the trial.

It is likely that a system of outcomes reporting is necessary in this field, both from the perspective of being able to identify centers providing excellent care, and for transparency about the learning curve in doing this type of procedure. Who might develop such a system or manage it was less clear, but one strong message was that whoever did so would by necessity come from a multidisciplinary perspective, given the range of disciplines working in this field. In other words, it will not work for a professional organization specifically representing obstetricians or pediatric surgeons to lead development of a reporting structure; conversely, a starting point may be an affiliation such as NAFTnet or the International Fetal Medicine and Surgery Society (IFMSS).

Nonetheless, the most comprehensive way to identify access to care at this point is to understand what care is available clinically and what is available to patients as research protocols. It is impossible to catalog the current level of innovative practice occurring in its pre-research stage. Therefore, currently funded trials are described in Appendix D. Interestingly, in some of the research reviewed, the ability to pay or be covered by insurance was an explicit inclusion criteria. The potential costs associated with a pregnant woman’s care following in utero procedures are extremely high and unpredictable. A tension exists between the need to continue to expand research and study of these procedures and the availability of research funding, particularly since research funding would be unlikely to cover unlimited or unanticipated medical costs associated with the procedure or recovery.

Ongoing research studies may also offer an opportunity for patients to access maternal-fetal treatment. Our key informants consistently stressed their concerns that all maternal-fetal surgical approaches should be evaluated in rigorous research, although they had differing opinions on what that might look like. Nonetheless, the field is characterized by a commitment to publishing in order to advance methodology and share new knowledge with colleagues. One concern that was raised both by key informants and in our literature search, however, is the dearth of information on harms reported in studies larger than single cases. In addition to the research listed in the table below, leaders in the field continue to innovate at their respective sites, including new device development and evaluation under FDA jurisdiction. Several key informants who discussed research efforts stressed the importance of clinical innovation taking place with the oversight of a data safety monitoring board, IRB and/or fetal or appropriate review board, even in the earliest stages. The ethical and consent issues associated with development of new surgical approaches and of spread of innovation were of significant interest to many of our key informants, who work hard to straddle a line of enthusiastic innovation and cautious realism about the potential for these interventions.

## Ethics and Issues of Consent

Indeed, as soon as physicians began performing maternal-fetal operations in the early 1980s, ethicists started weighing in on the moral, legal, and social implications of prenatal interventions.16–18 Maternal-fetal approaches raise moral issues at the intersections of abortion debates, disability rights, and self-determination claims. Fetal interventions can be framed as providing an alternative to abortion when prenatal diagnosis reveals that a fetus has congenital abnormalities that would lead to severe morbidity.16,19 While in utero surgeries can prevent elective abortions of some fetuses, the ability to correct certain fetal conditions during pregnancy may consequently exacerbate negative views in society of developmental and physical disabilities because they can become viewed as problems that should have been fixed or prevented.20–21 Moreover, the extent to which pregnant women have the right to refuse treatment that benefits their fetuses but exposes the women to risk has been called into question.22–25

Initially, in the 1980s the ethics literature focused predominantly on the ability of the legal system to force women to undergo fetal surgeries. While there were no reported cases of conflict that emerged from women refusing to consent to treatment, there was significant concern that fetal approaches were ripe for litigation. Some commentators predicted the inevitability of compulsory surgery being issued from the courts,26 and they proposed preemptive legislation to avoid the courts’ involvement.27 The pervasiveness of the ethical debate about the rights of women vis-à-vis the rights of the “not-yet-born child” was a product of the legal atmosphere of the 1980s.28 Specifically, the courts had become involved in legitimizing physicians’ control over the behavior of pregnant women as part of a broader movement to promote child welfare by diminishing parental authority.29 Courts issued orders forcing pregnant women to undergo cesarean sections, to consume drugs, or submit to prenatal screening, and they prosecuted women for drug and alcohol use.30–31

In large measure, the effect of these legal and ethical debates was to frame pregnant women and their fetuses in conflict,32 but there is no evidence that pregnant women understand their self-interest to be at odds with those of their fetuses.33–34 The conflict is more likely to arise between clinicians and pregnant women.35 This can be due to care providers’ perceptions that a pregnant woman is not appropriately willing to sacrifice her own interests for those of an “unborn child.”36 More likely, however, conflict occurs when physicians advise terminating the pregnancy in cases of fetal disability, but pregnant women desire to continue the pregnancy in spite of a grim prenatal diagnosis.37 Religious beliefs and values often play into these decisions to continue the pregnancy and prompt the decision to undergo in utero procedures.38–40

Discussions about the conflicting rights of pregnant women and fetuses have subsided to some extent since the mid-1990s. In part, this shift could be attributed to the recognition that maternal-fetal approaches did not have the outstanding benefits to fetuses that ethicists had anticipated.41–42 Taking a more measured view of existing interventions, ethicists began discussing the need to more thoroughly evaluate the therapeutic potential of fetal surgical treatment through the development of registries and clinical studies.43–44 A major thrust to this viewpoint was that defining fetal interventions as “innovation” instead of “research” created a system of insufficient oversight,45 particularly because innovation can be harmful and should be designed to minimize adverse outcomes.46 In addition to traditional ethicists’ involvement in these issues, social scientists began to take an active role in describing and analyzing practices that were actually occurring in fetal surgery centers.34,38,47–49 This approach to ethics has focused more attention on the informed consent process, including the social and cultural components to decisionmaking.38

The ethics debates about maternal-fetal surgical procedures draw attention to the differing risks of the procedures to pregnant women and fetuses. In addition to the medical risks to fetuses, pregnant women are exposed to the risks of anesthesia and surgery during the procedure, drugs to prevent premature labor and delivery after the procedure, and the emotional burden of consenting to medical interventions with uncertain outcomes.34 This means that the benefits of these surgeries always have to be considered within the context of the risks to both the pregnant woman and the fetus.

The practical implications of this are that informed consent procedures need to clearly explain all of the risks and benefits of the procedures and that benefits must be optimized through appropriate oversight of fetal interventions. For example, some ethicists have called for interdisciplinary teams to cooperate in the consent process by educating the pregnant woman (and her family) about her options, including but not limited to fetal interventions.6 In particular, some ethicists have stated that informed consent should be obtained only by a more neutral member of the care team rather than the surgeon.38 Because not everyone seeking fetal treatment is an appropriate candidate, the informed consent process should educate self-referring individuals so that their expectations about likely outcomes match current clinical realities. This view of consent underscores recent calls for more oversight of surgical innovations (both prospectively and retrospectively), more precise information about the benefits of fetal approaches in the context of the natural history of the diseases or disabilities being treated, and disclosure of information about the skill sets, experience, and success rates of medical teams performing each procedure. These measures would ensure that pregnant women (and their families) would have more robust information to use in their decisionmaking about fetal intervention.

## Background Information on Conditions Included

### Cardiac Malformations

Cardiac conditions for which in utero interventions are being performed are those in which there is a severe narrowing in one of the outflow tracts (aortic valve or pulmonary valve), causing progressive damage to the heart muscle in utero. There are three types of cardiac conditions for which in utero intervention is being performed: pulmonary atresia with intact ventricular septum (very narrow pulmonary valve without a connection between the right and left ventricles), critical aortic stenosis with impending hypoplastic left heart syndrome (very small, nonfunctional left ventricle, hypothesized by some investigators to be from underuse secondary to a severely narrow aortic valve), and hypoplastic left heart syndrome with intact atrial septum (no connection between the left and right atrium). All of these conditions, if untreated either in utero or soon after birth, are lethal.

Fetal surgery teams have proposed that in utero intervention can change the progression of the disease, allowing for more normal muscle to grow which can preserve function of both the ventricles in pulmonary atresia with intact ventricular septum and critical aortic stenosis with impending hypoplastic left heart syndrome (HLHS) and could obviate need for emergent atrial septostomy at birth for those patients with HLHS and intact atrial septum.

Critical pulmonary stenosis or atresia with intact ventricular septum. These anomalies portend a poor prognosis. A prospective prevalence study in Canada showed that overall survival was 77 percent at one month and 58 percent at 15 years. Only 33 percent ultimately end up with biventricular repair, 20 percent with Fontan repair, 20 percent with 1.5-ventricle repair, 5 percent with heart transplant, and 38 percent die before reaching definitive repair. Two percent of patients survived without definitive repair.50 Fetal intervention to relieve the stenosis and allow for ventricular growth could theoretically increase the number of patients who ultimately end up with a biventricular repair. There is some debate as to whether this is an adequate measure of success since the right ventricle in a two-ventricle repair still has abnormal diastolic dysfunction and may not lead to increased exercise capacity.51 However, these studies were performed in patients who had not undergone in utero repair. It is possible that if the stenosis is relieved early enough in gestation, there may be adequate time before delivery for growth of the right ventricle. In fetuses with impending hydrops, in utero valvuloplasty could reverse the condition and prevent hydrops and death.

Critical aortic stenosis. Severe aortic stenosis, which is a very narrow aortic valve that develops early during gestation, may result in hypoplastic left heart syndrome. If the stenosis develops in the first trimester, the left ventricle may be tiny by the time a morphological ultrasound is performed at around 20 weeks. However, if the stenosis develops closer to 20 weeks, the left ventricle may be hypertrophied or hypoplastic, but still visible. In utero aortic balloon valvuloplasty has been suggested as a way to relieve aortic stenosis, thus preserving left ventricular growth and halting progression to hypoplastic left heart syndrome.

The first described attempt at in utero balloon aortic valvuloplasty was reported by Maxwell in London in 1991. The same group reported the first survivor in a case report in 1995.^52^ Since then, there have been scattered attempts at this procedure around the world, but the most abundant work has been performed by the fetal surgery team at Children’s Hospital Boston, Massachusetts.

Hypoplastic left heart syndrome and intact atrial septum. A subset of patients with hypoplastic left heart syndrome (HLHS) with an intact or highly restrictive atrial septum will present with severe cyanosis and require immediate postnatal intervention in order to survive. This accounts for approximately 5.7 percent to 11 percent of newborns with HLHS.53–54 CDC estimates that each year about 975 babies in the United States are born with HLHS.55–56 In other words, each year about 2 out of every 10,000 babies born will be born with HLHS. The approaches that have been used include an emergent stage I palliation, the Norwood procedure, which has a poor survival rate in this scenario (10–28 percent)54,57–58 or a neonatal catheter atrial septostomy. In Vlahos’s study, patients requiring an urgent neonatal catheter septostomy to decompress the left atrium have a 21 percent mortality before stage I palliation compared to no mortality before a Norwood in patients with an unrestrictive atrial septal defect.59

Given the high mortality of infants with HLHS and intact atrial septum, considered to be due to the pulmonary vasculopathy that develops before birth, in utero atrial septostomy has been performed in an attempt to improve postnatal survival. The first report of a balloon atrial septoplasty was in 2004. There is also a single case report using a laser to perform atrial septoplasty.60 The balloon atrial septoplasty is performed percutaneously with access usually to the fetal right atrium after traversing the maternal abdominal wall, uterine wall, and fetal chest wall using an 18- or 19-gauge introducer cannula mounted on a metal obturator.57 The introducer is advanced into the right atrium and the atrial septum is punctured by the tip of the introducer or with a 22-gauge Chiba needle. A wire is then introduced through the Chiba needle into the left atrium or a pulmonary vein and the needle is exchanged for a balloon angioplasty catheter. The balloon is fully inflated twice. In two cases teams approached the atrial septum from the left atrium. In two cases teams were unable to achieve technical success due to inability to reach the fetal left atrium.54

### Congenital Diaphragmatic Hernia

Congenital diaphragmatic hernia (CDH) results from abnormal development of the diaphragm, which allows abdominal organs such as the bowel, the stomach, and the liver to protrude into the chest cavity. CDH is an important, relatively common congenital malformation, with incidence in the United States of approximately 1 in every 2,500 births.61–62 Fetuses diagnosed in utero as a result of maternal symptoms have mortality risk approaching 75 percent in some older reviews. One of the paradoxes of diaphragmatic hernia care is a trend toward improved outcome of fetuses not diagnosed before birth. This may reflect the fact that less-severe lesions, without the findings of liver in the chest, stomach in the chest, or increased amniotic fluid volume are less likely to be detected by routine ultrasound. Like all fetal diagnoses, the ability to detect less-severe lesions has improved over time, as has our understanding of fetal lung physiology and advances in ventilator and NICU care, and thus the mortality estimates for defects detected during pregnancy, is continually changing.

After developing techniques for fetal surgical procedures in animal models, the initial attempts to repair CDH in utero were done via open hysterotomy followed by thoracotomy and repair of the defect. This work was hampered by technical challenges, including the inability to prevent preterm birth after a prolonged open uterus surgery and inability of the fetus to tolerate the surgical procedure, which included major manipulation of the liver through which the blood flow from the placenta is delivered. When the procedure was done in fetuses without liver involvement, it was learned that the group who received care at birth had 86 percent survival,63 making the risks of preterm birth from in utero repair less acceptable. Subsequently, new understanding of the pathophysiology of lung fluid and growth suggested that a less invasive approach could be successful. Occluding the trachea of a fetus results in buildup of lung secretions in the pulmonary tree, gradually distending the lungs as well as triggering complex changes in maturation, including DNA synthesis, epithelial and endothelial proliferation, increased phospholipid metabolism and surfactant synthesis. The growing lungs push the bowel and abdominal contents out of the chest cavity to an extent and promote improved lung growth. Less-invasive fetal surgeries have more recently focused on methods to accomplish tracheal occlusion.

### Myelomeningocele/Spina Bifida

Myelomeningocele (MMC) is a congenital malformation in which the meninges and spinal cord protrude through a defect in the vertebral arches, muscle, and skin. It is the most commonly observed malformation of the central nervous system, affecting more than 1,000 fetuses in the United States annually.64 MMC is the most common form of spina bifida, and although it is rarely fatal, individuals affected with it have a range of disabilities, including paraplegia, hydrocephalus, skeletal deformities, bowel and bladder incontinence and cognitive impairment. It is generally associated with Arnold Chiari malformation (CM), which is often associated with the observed hydrocephalus in these patients. The genesis of CM and its association with the MMC lesion is not entirely understood, but may be due to leaking cerebrospinal fluid.

The etiology of MMC is not entirely understood, although it likely has a genetic component and may be environmentally driven as well.65 There is good evidence that folate reduces the incidence of neural tube defects, including this one, but does not inevitably prevent them. The standard treatment has been to close the defect postnatally, and shunting for hydrocephalus is common.

In the early 1990s, animal experiments suggested that the neurologic damage to the spinal cord might be partially due to the exposure of the uncovered neural elements to trauma and amniotic fluid during the pregnancy. This is known as the “two-hit hypothesis” in which the first insult is the defect itself, and the second is the toxic effect of amniotic fluid on the exposed meninges and spinal cord. The hypothesis was supported by the observation that fetal leg movement may be observed up to about 17 weeks’ gestation in fetuses with MMC, but subsequently ceases. Animal research suggested that covering the defect early on could potentially result in better lower extremity and bladder function. Myelomeningocele repair was the first in utero surgery considered for a nonlethal malformation on the basis that its natural history was well known and leads to lifelong disability in the absence of intervention. Furthermore, the defect can be diagnosed prenatally in over 80 percent of cases by maternal serum alpha-fetoprotein and ultrasound; MRI is used to detect specific anomalies and disease process.

The procedure was initially performed by Bruner and colleagues as a closed laparoscopic covering of the spinal defect, with the first case reported in a letter and in a series of four fetuses published in 1999 (the surgeries were conducted between 1994 and 1997).66 Half of the fetuses survived, and both survivors required shunting. In a continuation of this work, four fetuses were operated on using an open approach and compared to four done endoscopically,67 and the open surgery showed improved outcomes, while the endoscopic approach had high mortality. The endoscopic approach has been abandoned, and therefore the rest of this overview will focus on literature related to open surgery for MMC repair. Since 1997, more than 200 fetuses with MMC have undergone open surgical repair in the United States.

### Obstructive Uropathy

A variety of fetal malformations can lead to distention of the urinary bladder; these include urethral atresia (failure of the bladder stem to properly form so urine cannot exit), posterior urethral valves (which in male fetuses can prevent flow of urine through the full length of the urethra); and megacystis-megaureter-microcolon syndrome (which results from malformation of the organs rather than frank blockage of urine flow), and Prune-belly syndrome (which includes lack of development of abdominal muscles, undescended testicles, and urinary anomalies). Other urinary tract anomalies can result in distension of one or both ureters, such as blockage at the junction with the bladder or at any place along the ureter, which conveys urine from the kidney to the bladder. In this case when there is renal function and a ureteral impass, the distended portion of the urinary tract is the ureter or renal pelvis rather than the bladder.

Goals of fetal therapy have emphasized decompression rather than repair of the specific lesion. The goal of decompression of the distended portion of the urinary tract is to protect remaining renal function and promote lung development. While it is simplistic to attribute these resulting changes to a simple mechanism such as pressure relief on the developing kidney or movement of a column of amniotic fluid up and down the lower respiratory tree, the relief of urinary tract pressure and the presence of amniotic fluid are correlated with improved renal and pulmonary function at birth in some infants. Placement of an indwelling shunt to decompress fetal urinary tract distension was first reported in 1982.^68^ The care team placed a shunt from the bladder to the amniotic cavity by insertion under ultrasound guidance through the maternal skin with a puncture, but not open surgery. This first case by a percutaneous approach was performed at 30 weeks gestation.68 In rapid succession, clinical investigators began to intervene earlier in pregnancy with treatment before 18 weeks reported in 1983.^69^ Open procedures to correct the urinary tract anomaly, using techniques similar to those used after birth, have also been reported in the earlier literature. Challenges with increased preterm birth and comparable outcomes with the shunting procedures have resulted in a trend to percutaneous shunting procedures dominating the literature. After a small incision in the maternal skin, generally with local anesthesia only, the shunt is inserted through an introducer sheath into position within the fetal bladder. An internal guide or stylus within the shunt is withdrawn allowing a prefabricated curl or “pigtail” to form at the distal end that helps hold the device within the fetal bladder. As the introducer is completely withdrawn, a second pigtail forms on the opposite end to hold the shunt outside the fetus and to assure drainage of urine into the amniotic cavity. When the shunt type or method was noted by authors to vary from this, we have indicated the difference.

### Sacrococcygeal Teratoma

Sacrococcygeal teratoma (SCT) is a relatively rare condition effecting approximately 1 in 40,000 fetuses or about 100 infants a year in the United States. As a result of ultrasound use, these tumors are increasingly recognized antenatally. The outcomes of prenatally diagnosed, uncomplicated survivors to term are generally good. However, those fetuses with large, vascular tumors have a high incidence of prenatal mortality from high-output cardiac failure or spontaneous hemorrhage into or rupture of the growing tumor. Among fetuses followed in series without hydrops, survival ranges from 32 percent70 and 48 percent71 among infants with high output cardiovascular changes or associated anomalies to 83 percent,72 92 percent,73 and 100 percent in uncomplicated cases.74–75 Fetal surgical procedures for SCT have focused on the small subgroup of fetuses with SCT and hydrops because untreated cases are expected to die in utero or at birth. All series report 100 percent mortality.70–76 In severe cases, SCT with hydrops is associated with maternal risks. Mothers of fetuses with hydrops can develop mirror syndrome, which is a severe form of pre-eclampsia and can be associated with placentomegaly. Mirror syndrome is a maternal contraindication to fetal approaches since the mother is critically ill and delivery has been felt to be indicated for maternal health. Consequently, decisions to intervene need to be made when the fetus is documented to be critically ill while the mother is still in good health.

### Thoracic Lesions

Congenital pulmonary airway malformations (CPAM), which include congenital cystic adenomatoid malformation (CCAM) and bronchopulmonary sequestration (BPS), are congenital anomalies of the lung that share the characteristic of a segment of lung being replaced by abnormally developing tissue. CCAMs can have connections to the pulmonary tree and contain air. The tissue is served by blood vessels in the pulmonary circulation.77 BPS does not connect to the airway and has blood flow from branches off the aorta as well as the pulmonary circulation. Antenatal diagnosis is most often made by ultrasound.

Only a small subset of patients with congenital pulmonary airway malformations are candidates for in utero treatment. In this subset, the mass is large enough and in such an anatomically critical position that the fetal mediastinum is compressed, leading to impaired venous return with resulting fetal hydrops secondary to cardiac failure. When this occurs early enough in gestational age that delivery and postnatal treatment are not an option, in utero treatment is a possible solution. The majority of CPAMs, however, do not have an indication for prenatal treatment as the outcomes are excellent, with the tumors often regressing throughout pregnancy and causing no neonatal or early childhood symptoms.

Oftentimes one of the more difficult judgments to be made during pregnancy is the frequency with which these tumors should be monitored to detect the small percentage that will cause fetal harm in order to know when to intervene. Distinguishing between these conditions is difficult and some would argue clinically irrelevant until after birth. The final common pathway that leads to consideration of fetal intervention is the same—fetal hydrops—whether the lesion is considered a pure CCAM, BPS, or a hybrid lesion. Evaluation of 40 infants classified as having BPS found 50 percent of infants had elements of CCAM on their lung pathology.78

The diagnosis of CCAM is likewise not always certain until after surgery. In separate series 4 of 33 suspected CCAMs had BPS upon pathologic exam;79 six of nine had “hybrid lesions”(CCAM and sequestration present in the same lesion), and 16 of 37 were lesions other than CCAM. In a report from a busy fetal center with 4,551 patients, 38 cases of thoracic lesions were identified, and three of them were BPS.80 Based on this considerable overlap, Achiron and colleagues suggested a new classification of lung lesions based on vascular supply which has not yet been adopted.81

By convention CCAM lesions are grouped into three types: type one is a lesion composed of single or multiple large cysts (more than 2 centimeters in diameter); type two is multicystic composed of multiple small cysts (less than 1 centimeter in diameter); and type three is a solid lesion.82 The potential for shunt placement depends upon the type of lesion. Cystic lesions may be drained, but other types are resected.

These lung malformations have a variable course in utero. Natural history reports suggest that the majority of CCAM lesions increase in size in midtrimester and either involute in the third trimester or cause a compressive effect on the fetal thorax resulting in hydrops in the fetus and occasionally a mirror syndrome illness in the mother.83–84 There are presently no useful predictors of outcome, and serial evaluations are essential to determine course. Hydrops in the fetus results from obstruction of the vena cava and cardiac compression caused by mediastinal shift.85 The decision to intervene in utero is often based on the natural history reports that hydrops marks a transition to fetal demise. In 1985, Adzick and colleagues reported on 11 fetuses with CCAM and hydrops with 100 percent mortality.86 Hydrops in BPS may result from somewhat different mechanisms with tension hydrothorax increasing thepressure within the thorax and decreasing venous and lymphatic return to the heart. Hydrops in these fetuses has also been reported to usually be fatal if untreated in utero, with only 1 survivor in 33 cases.87

At times, large pleural effusions occur without CCAM or BPS, the natural history of these effusions is even less well understood. We did not include interventions for isolated pleural effusions in this review; neither did we include papers that only reported thoracocentesis as a treatment.

### Twin-Twin Transfusion Syndrome

Background. In twin-to-twin transfusion syndrome (TTTS), twins share a single chorionic membrane and therefore, a single placenta, but have separate amniotic sacs. Approximately 15 percent of monochorionic, diamniotic twin pregnancies are affected by TTTS,88 and therefore, estimates based on CDC data are that theoretical incidence of TTTS would be about 1.38 to 1.86 cases per 1,000 live births.89 Although incidence studies have found lower numbers, these numbers are probably a reflection of early deaths of affected fetuses in utero that therefore do not get recognized as TTTS pregnancies.

In TTTS, one twin (the donor) transfuses the other twin (the recipient) through intertwin placental vascular anastomoses (or communications). When this occurs, the donor twin becomes hypovolemic, resulting in decreased renal perfusion. Decreased perfusion may result in renal pathology, thus reducing urinary output and amniotic fluid volume in the donor twin’s amniotic sac (oligohydramnios). The recipient twin, conversely, is hypervolemic with increased renal perfusion resulting in polyhdramnios. As the overproduction of urine continues, the polyhydramniotic sac can expand and cause uterine distention, leading to premature labor and delivery. Most pregnancies presenting with severe TTTS prior to 26 weeks and not undergoing some sort of therapy will end with dual fetal demise.88 When both twins do survive, there is often severe neurologic compromise in survivors as well as other organ failure, including cardiac conditions. Approximately 25 percent of surviving fetuses in a monochorionic twin pair in which one dies will suffer CNS injury. This is thought to be related to either transplacental passage of cytokines and vasoactive compounds or a result of cerebral ischemia related to hypotension from exsanguinations of the survivor into the vascular bed of the dead twin.

The first reported case of twin-to-twin transfusion was in 1942^90^ and was referenced in 1964, when DeMarco91 postulated that some aspects of this disorder were explainable by an in utero placental shunt in monozygous twins. The early descriptions often depicted what is likely now known as acute twin-twin transfusion syndrome and were based on live born twins who had sometimes dramatically different hemoglobin levels and birth weights. With the development of ultrasonography, however, we have learned that the cascade of events leading to this outcome begins early, and classic TTTS findings are late manifestations of the condition.92–93

With this new information, diagnostic criteria for TTTS evolved to include: same-sex fetuses with a single placenta with lack of lambda sign in early pregnancy; oligohydramnios in the donor sac (<2 cm maximum vertical pocket) and polyhydramnios in the recipient sac (>8 cm maximum vertical pocket at less than 20 weeks or >10 cm after 20 weeks).

After diagnosis, the most common approach to assessing severity in TTTS is the Quintero staging system:94

- Stage I: The fetal bladder of the donor twin remains visible sonographically.
- Stage II: The bladder of the donor twin is collapsed and not visible by ultrasound.
- Stage III: Critically abnormal fetal Doppler studies noted. This may include absent or reversed end-diastolic velocity in the umbilical artery, absent or reverse flow in the ductus venosus, or pulsatile flow in the umbilical vein.
- Stage IV: Fetal hydrops present.
- Stage V: Demise of one or both twins.

In 1990, Baldwin and Wittman95 presented three prenatally diagnosed twin pairs with in utero twin transfusion syndrome for which they attempted selective reduction. They postulated the importance of a vascular separation. Later that year, De Lia et al. reported the first fetal surgery to treat the underlying pathology.96

Four primary approaches exist for intervening in twin-to-twin transfusion syndrome:

- Serial amnioreduction to relieve intra-amniotic pressure and uterine size, and thus prolong the pregnancy. Although the mechanism by which it works is not entirely clear, amnioreduction has been associated with a 50–60 percent survival rate of at least one fetus.97
- Termination of the sicker twin, which is likely to rescue the healthier one and is accomplished by cord occlusion, radio frequency ablation, or ligation. This is only used in the presence of significant birth defects.
- Septostomy, in which the intervening membrane is punctured to attempt to increase amniotic fluid in the oligohydramniotic sac, was performed but has largely been abandoned as a therapy.98
- Laser ablation of communicating vessels; it is performed either selectively or nonselectively to attempt to protect one twin from hemodynamic disturbances in the other twin. In nonselective ablation, all vessels crossing the dividing membrane are ablated, whereas selective ablation is limited to vessels shown to be communicating between the two fetuses. Selective ablation is most common today, and is the focus of this section of the technical brief. Gaining access to the uterus can be accomplished in three ways: laparotomy to expose the uterus, laparoscopic placement of the fetoscope, and ultrasound-guided placement of the fetoscope.

Gaining access to the uterus can be accomplished in three ways: laparotomy to expose the uterus, laparoscopic placement of the fetoscope, and ultrasound-guided placement of the fetoscope.

## References

1 Liley AW. Intrauterine transfusion of foetus in haemolytic disease. Br Med J. 11. 2. 1963;2(5365):1107-1109. [pmid: 14057715].
2 Farrell JA. Fetal treatment center: history, infrastructure, and nursing perspective. J Perinat Neonatal Nurs. 01–03. 2007;21(1):11-9. quiz 20–21. [pmid: 17301662].
3 Chescheir NC, Socol M. The national institutes of health workshop on fetal treatment: needs assessment and future directions. Obstet Gynecol. 10. 2005;106(4):828-833. [pmid: 16199643].
4 Bruner JP. In their footsteps: a brief history of maternal-fetal surgery. Clin Perinatol. 09. 2003;30(3):439-447. [pmid: 14533887].
5 International Fetal Medicine and Surgery Society. 2009. Available at: http://www.ifmss.org. Accessed July 1, 2010.
6 Harrison MR. Fetal surgery: trials, tribulations, and turf. J Pediatr Surg. 03. 2003;38(3):275-282. [pmid: 12632335].
7 Wilkinson LG, Powell RW, Cabaniss ML, et al. Surgical problems in the fetus: a multidisciplinary approach. Am J Surg. 12. 1987;154(6):685-687. [pmid: 3425818].
8 Luks FI, Carr SR, Feit LR, et al. Experience with a multidisciplinary antenatal diagnosis and management model in fetal medicine. J Matern Fetal Neonatal Med. 11. 2003;14(5):333-337. [pmid: 14986808].
9 Moise KJ Jr, Johnson A, Carpenter RJ, et al. Fetal intervention: providing reasonable access to quality care. Obstet Gynecol. 02. 2009;113(2 Pt 1):408-410. [pmid: 19155914].
10 Chan FY, Soong B, Taylor A, et al. Fetal endoscopic telesurgery using an Internet Protocol connection: clinical and technical challenges. J Telemed Telecare. 2003;9(Suppl 2):S12-S14. [pmid: 14728749].
11 Quintero RA, Munoz H, Pommer R, et al. Operative fetoscopy via telesurgery. Ultrasound Obstet Gynecol. 10. 2002;20(4):390-391. [pmid: 12383324].
12 Bannister CM. Fetal neurosurgery—a new challenge on the horizon. Dev Med Child Neurol. 12. 1984;26(6):827-830. [pmid: 6542889].
13 Harrison MR, Adzick NS. The fetus as a patient. Surgical considerations. Ann Surg. 04. 1991;213(4):279-291. discussion 277–278. [pmid: 2009009].
14 Han SJ, Hwang EH. The development of fetal surgery. Yonsei Med J. 12. 2001;42(6):602-608. [pmid: 11754143].
15 Peeters S, Oepkes D, Lopriore E, et al. Fetoscopic laser coagulation in twin-twin transfusion syndrome: the learning curve [abstract]. Am J Obstet Gynecol. 2007;197:S162.
16 Barclay WR, McCormick RA, Sidbury JB, et al. The ethics of in utero surgery. JAMA. 10. 2. 1981;246(14):1551-1552. [pmid: 6792373].
17 Ruddick W, Wilcox W. Operating on the fetus. Hastings Cent Rep. 10. 1982;12(5):10-14. [pmid: 7174290].
18 Robertson JA. The right to procreate and in utero fetal therapy. J Leg Med. 09. 1982;3(3):333-366. [pmid: 6983547].
19 Robertson JA. Legal issues in prenatal therapy. Clin Obstet Gynecol. 09. 1986;29(3):603-611. [pmid: 3757338].
20 Engelhardt HT Jr. Current controversies in obstetrics: wrongful life and forced fetal surgical procedures. Am J Obstet Gynecol. 02. 1. 1985;151(3):313-318. [pmid: 3970098].
21 Strauss RP, Davis JU. Prenatal detection and fetal surgery of clefts and craniofacial abnormalities in humans: social and ethical issues. Cleft Palate J. 04. 1990;27(2):176-182. discussion 182–183. [pmid: 2340638].
22 Fletcher JC. Drawing moral lines in fetal therapy. Clin Obstet Gynecol. 09. 1986;29(3):595-602. [pmid: 3757337].
23 Goldman EB. Fetal versus maternal rights: who is the patient?. Mich Hosp. 04. 1983;19(4):23-25. [pmid: 10259175].
24 Gilmore A. Is the fetus a patient. Can Med Assoc J. 06. 15. 1475. 1983;128(12):1472-1476. [pmid: 6850473].
25 Pringle KC. Fetal surgery: it has a past, has it a future?. Fetal Ther. 1986;1(1):23-31. [pmid: 3333205].
26 Kindregan C. Compulsory fetal surgery: an issue for the future. Report Hum Reprod Law. 03-04. Reports. 1984:111-112.
27 Knopoff KA. Can a pregnant woman morally refuse fetal surgery?. Calif Law Rev. 03. 1991;79(2):499-540. [pmid: 11659841].
28 Murray TH. Moral obligations to the not-yet born: the fetus as patient. Clin Perinatol. 06. 1987;14(2):329-343. [pmid: 3595055].
29 Rauscher K. Fetal surgery: a developing legal dilemma. St Louis Univ Law J. 09. 1987;31(3):775-795. [pmid: 11658987].
30 Weinberg SR. A maternal duty to protect fetal health?. Indiana Law J. 1983;58(3):531-46. [pmid: 16211746].
31 Lenow JL. The fetus as a patient: emerging rights as a person?. Am J Law Med. Spring. 1983;9(1):1-29. [pmid: 6638018].
32 Morris C. Technology and the legal discourse of fetal autonomy. UCLA Womens Law J. Fall–Winter. 1997;8(1):47-97. [pmid: 16273687].
33 Blank RH. Emerging notions of women’s rights and responsibilities during gestation. J Leg Med. 12. 1986;7(4):441-469. [pmid: 3492583].
34 Bliton MJ. Parental hope confronting scientific uncertainty: a test of ethics in maternal-fetal surgery for spina bifida. Clin Obstet Gynecol. 09. 2005;48(3):595-607. [pmid: 16012227].
35 Brown D, Andersen HF, Elkins TE. An analysis of the ACOG and AAP ethics statements on conflicts in maternal-fetal care. J Clin Ethics. Spring. 1991;2(1):19-22. discussion 23–24. [pmid: 1932792].
36 Howe EG. Unicorns, Carravaggio, and fetal surgery. J Clin Ethics. Winter. 2001;12(4):333-345. [pmid: 12026739].
37 Bliton MJ, Zaner RM. Over the cutting edge: how ethics consultation illuminates the moral complexity of open-uterine fetal repair of spina bifida and patients’ decision making. J Clin Ethics. Winter. 2001;12(4):346-360. [pmid: 12026740].
38 Rothschild BB, Estroff SE, Churchill LR. The cultural calculus of consent. Clin Obstet Gynecol. 09. 2005;48(3):574-594. [pmid: 16012226].
39 Gonzalez-Abreu MM. Parental voices: You get what you get and you don’t get upset: a child’s answer to life’s biggest challenges. Clin Obstet Gynecol. 09. 2005;48(3):527-533. [pmid: 16012221].
40 Kennedy D, Kennedy L. Parental voices: our journey of grace. Clin Obstet Gynecol. 09. 2005;48(3):534-539. [pmid: 16012222].
41 Elias S, Annas GJ. Perspectives on fetal surgery. Am J Obstet Gynecol. 04. 1. 1983;145(7):807-812. [pmid: 6682291].
42 Pendl G. Symposium on ethics and morals related to antenatal treatment of pediatric neurosurgical disorders. Treatment of fetuses in utero—an opinion from central Europe. Childs Nerv Syst. 06. 1988;4(3):158-160. [pmid: 3396023].
43 Lyerly AD, Mahowald MB. Maternal-fetal surgery for treatment of myelomeningocele. Clin Perinatol. 03. 2003;30(1):155-165. [pmid: 12696793].
44 Manning FA. Fetal surgery for obstructive uropathy: rational considerations. Am J Kidney Dis. 10. 1987;10(4):259-267. [pmid: 3310616].
45 Reitsma AM, Moreno JD. Maternal-fetal research and human research protections policy. Clin Perinatol. 03. 2003;30(1):141-153. [pmid: 12696792].
46 Chervenak FA, McCullough LB. A comprehensive ethical framework for fetal research and its application to fetal surgery for spina bifida. Am J Obstet Gynecol. 07. 2002;187(1):10-14. [pmid: 12114882].
47 Casper MJ. Making of the Unborn Patient: A Social Anatomy of Fetal Surgery. New Brunswick, NJ. Rutgers University Press. 1998.
48 Blizzard D. Looking Within: A Sociocultural Examination of Fetoscopy. Cambridge, MA. MIT Press. 2007.
49 Williams C. Dilemmas in fetal medicine: premature application of technology or responding to women’s choice?. Sociol Health Illn. 01. 2006;28(1):1-20. [pmid: 16509940].
50 Ashburn DA, Blackstone EH, Wells WJ, et al. Determinants of mortality and type of repair in neonates with pulmonary atresia and intact ventricular septum. J Thorac Cardiovasc Surg. 04. 2004;127(4):1000-1007. discussion 1007–1008. [pmid: 15052196].
51 Shinebourne EA, Rigby ML, Carvalho JS. Pulmonary atresia with intact ventricular septum: from fetus to adult: congenital heart disease. Heart. 10. 2008;94(10):1350-1357. [pmid: 18801793].
52 Allan LD, Maxwell DJ, Carminati M, et al. Survival after fetal aortic balloon valvoplasty. Ultrasound Obstet Gynecol. 02. 1995;5(2):90-91. [pmid: 7719873].
53 Tulzer G, Arzt W, Franklin RC, et al. Fetal pulmonary valvuloplasty for critical pulmonary stenosis or atresia with intact septum. Lancet. 11. 16. 2002;360(9345):1567-1568. [pmid: 12443597].
54 Glatz JA, Tabbutt S, Gaynor JW, et al. Hypoplastic left heart syndrome with atrial level restriction in the era of prenatal diagnosis. Ann Thorac Surg. 11. 2007;84(5):1633-1638. [pmid: 17954074].
55 Hospital stays, hospital charges, and inhospital deaths among infants with selected birth defects—United States, 2003. MMWR Morb Mortal Wkly Rep. 01. 19. 2007;56(2):25-29. [pmid: 17230142].
56 National Center on Birth Defects and Developmental Disabilities. Metropolitan Atlanta Congenital Defects Program 2004 Annual Report. Atlanta, GA. Centers for Disease Control and Prevention. 2004.
57 Hehir DA, Dominguez TE, Ballweg JA, et al. Risk factors for interstage death after stage 1 reconstruction of hypoplastic left heart syndrome and variants. J Thorac Cardiovasc Surg. 07. 2008;136(1):94-99. 99 e1. 3. [pmid: 18603060].
58 Rychik J, Rome JJ, Collins MH, et al. The hypoplastic left heart syndrome with intact atrial septum: atrial morphology, pulmonary vascular histopathology and outcome. J Am Coll Cardiol. 08. 1999;34(2):554-560. [pmid: 10440172].
59 Vlahos AP, Lock JE, McElhinney DB, et al. Hypoplastic left heart syndrome with intact or highly restrictive atrial septum: outcome after neonatal transcatheter atrial septostomy. Circulation. 05. 18. 2004;109(19):2326-2330. [pmid: 15136496].
60 Quintero RA, Huhta J, Suh E, et al. In utero cardiac fetal surgery: laser atrial septotomy in the treatment of hypoplastic left heart syndrome with intact atrial septum. Am J Obstet Gynecol. 10. 2005;193(4):1424-1428. [pmid: 16202736].
61 Rudolph CD, Rudolph AM, Hostetter MK, et al., editors. Rudolph’s pediatrics. New York. McGraw-Hill Medical Pub. Div. 2003.
62 Butler N, Claireaux AE. Congenital diaphragmatic hernia as a cause of perinatal mortality. Lancet. 03. 31. 1962;1(7231):659-663. [pmid: 13875198].
63 Harrison MR, Adzick NS, Bullard KM, et al. Correction of congenital diaphragmatic hernia in utero VII: a prospective trial. J Pediatr Surg. 11. 1997;32(11):1637-1642. [pmid: 9396545].
64 Mathews TJ, Honein MA, Erickson JD. Spina bifida and anencephaly prevalence—United States, 1991–2001. MMWR Recomm Rep. 09. 13. 2002;51(RR-13):9-11. [pmid: 12353510].
65 Fichter MA, Dornseifer U, Henke J, et al. Fetal spina bifida repair—current trends and prospects of intrauterine neurosurgery. Fetal Diagn Ther. 2008;23(4):271-286. [pmid: 18417993].
66 Bruner JP, Richards WO, Tulipan NB, et al. Endoscopic coverage of fetal myelomeningocele in utero. Am J Obstet Gynecol. 01. 1999;180(1 Pt 1):153-158. [pmid: 9914596].
67 Bruner JP, Tulipan NB, Richards WO, et al. In utero repair of myelomeningocele: a comparison of endoscopy and hysterotomy. Fetal Diagn Ther. 03–04. 2000;15(2):83-8. [pmid: 10720871].
68 Golbus MS, Harrison MR, Filly RA, et al. In utero treatment of urinary tract obstruction. Am J Obstet Gynecol. 02. 15. 1982;142(4):383-288. [pmid: 7199255].
69 Manning FA, Harman CR, Lange IR, et al. Antepartum chronic fetal vesicoamniotic shunts for obstructive uropathy: A report of two cases. Am J Obstet Gynecol. 04. 1. 1983;145(7):819-822. [pmid: 6837660].
70 Flake AW. Fetal sacrococcygeal teratoma. Semin Pediatr Surg. 05. 1993;2(2):113-120. [pmid: 8062028].
71 Bond SJ, Harrison MR, Schmidt KG, et al. Death due to high-output cardiac failure in fetal sacrococcygeal teratoma. J Pediatr Surg. 12. 1990;25(12):1287-1291. [pmid: 2286911].
72 Neubert S, Trautmann K, Tanner B, et al. Sonographic prognostic factors in prenatal diagnosis of SCT. Fetal Diagn Ther. 07–08. 2004;19(4):319-326. [pmid: 15192290].
73 Uchiyama M, Iwafuchi M, Naitoh M, et al. Sacrococcygeal teratoma: a series of 19 cases with long-term follow-up. Eur J Pediatr Surg. 06. 1999;9(3):158-162. [pmid: 10427491].
74 Chisholm CA, Heider AL, Kuller JA, et al. Prenatal diagnosis and perinatal management of fetal sacrococcygeal teratoma. Am J Perinatol. 1999;16(1):47-50. [pmid: 10362082].
75 Westerburg B, Feldstein VA, Sandberg PL, et al. Sonographic prognostic factors in fetuses with sacrococcygeal teratoma. J Pediatr Surg. 02. 2000;35(2):322-325. discussion 325–326. [pmid: 10693688].
76 Schmidt KG, Silverman NH, Harison MR, et al. High-output cardiac failure in fetuses with large sacrococcygeal teratoma: diagnosis by echocardiography and Doppler ultrasound. J Pediatr. 06. 1989;114(6):1023-1028. [pmid: 2656957].
77 Pumberger W, Hormann M, Deutinger J, et al. Longitudinal observation of antenatally detected congenital lung malformations (CLM): natural history, clinical outcome and long-term follow-up. Eur J Cardiothorac Surg. 11. 2003;24(5):703-711. [pmid: 14583302].
78 Burdis L, Koch DD. The use of cardiopulmonary bypass and extracorporeal membrane oxygenation for support during removal of two teratomas and hydrops fetalis. J Extra Corpor Technol. 06. 2004;36(2):182184.
79 Dommergues M, Louis-Sylvestre C, Mandelbrot L, et al. Congenital adenomatoid malformation of the lung: when is active fetal therapy indicated?. Am J Obstet Gynecol. 10. 1997;177(4):953-958. [pmid: 9369851].
80 Crombleholme TM, D’Alton M, Cendron M, et al. Prenatal diagnosis and the pediatric surgeon: the impact of prenatal consultation on perinatal management. J Pediatr Surg. 01. 1996;31(1):156-162. discussion 162–163. [pmid: 8632271].
81 Achiron R, Zalel Y, Lipitz S, et al. Fetal lung dysplasia: clinical outcome based on a new classification system. Ultrasound Obstet Gynecol. 08. 2004;24(2):127-133. [pmid: 15287048].
82 Stocker JT, Madewell JE, Drake RM. Congenital cystic adenomatoid malformation of the lung. Classification and morphologic spectrum. Hum Pathol. 03. 1977;8(2):155-171. [pmid: 856714].
83 Gornall AS, Budd JL, Draper ES, et al. Congenital cystic adenomatoid malformation: accuracy of prenatal diagnosis, prevalence and outcome in a general population. Prenat Diagn. 12. 15. 2003;23(12):997-1002. [pmid: 14663837].
84 Adzick NS, Harrison MR, Crombleholme TM, et al. Fetal lung lesions: management and outcome. Am J Obstet Gynecol. 10. 1998;179(4):884-889. [pmid: 9790364].
85 Harrison MR, Adzick NS, Jennings RW, et al. Antenatal intervention for congenital cystic adenomatoid malformation. Lancet. 10. 20. 1990;336(8721):965-967. [pmid: 1977005].
86 Adzick NS, Harrison MR, Glick PL, et al. Fetal cystic adenomatoid malformation: prenatal diagnosis and natural history. J Pediatr Surg. 10. 1985;20(5):483-488. [pmid: 3903097].
87 Grethel EJ, Wagner AJ, Clifton MS, et al. Fetal intervention for mass lesions and hydrops improves outcome: a 15-year experience. J Pediatr Surg. 01. 2007;42(1):117-123. [pmid: 17208551].
88 Johnson A, Moise KJ Jr. Improving survival in twin-twin transfusion syndrome. Contemporary OB/GYN. 2006;51(12):54-59.
89 Martin JA, Hamilton BE, Sutton PD, et al. Births: final data for 2003. Natl Vital Stat Rep. 09. 8. 2005;54(2):1-116.
90 Herlitz G. Zur Kenntnis der anämischen Und polyzytamischen Zustände bei Neugeborenen sowie des Icterus gravis neonatorum. Acta Paediatrica (Upsala). 1942;29:211.
91 Demarco PG. Feto-fetal transfusions in monozygotic twins: review of the literature and report of two cases. Clin Pediatr (Phila). 12. 1964;3:709-713. [pmid: 14223779].
92 Chescheir NC, Seeds JW. Polyhydramnios and oligohydramnios in twin gestations. Obstet Gynecol. 06. 1988;71(6 Pt 1):882-884. [pmid: 3285268].
93 Brown DL, Benson CB, Driscoll SG, et al. Twin-twin transfusion syndrome: sonographic findings. Radiology. 01. 1989;170(1 Pt 1):61-63. [pmid: 2642349].
94 Quintero RA, Morales WJ, Allen MH, et al. Staging of twin-twin transfusion syndrome. J Perinatol. 12. 1999;19(8 Pt 1):550-555. [pmid: 10645517].
95 Baldwin VJ, Wittmann BK. Pathology of intragestational intervention in twin-to-twin transfusion syndrome. Pediatr Pathol. 1990;10(1–2):79-93. [pmid: 2179921].
96 De Lia JE, Cruikshank DP, Keye WR Jr. Fetoscopic neodymium:YAG laser occlusion of placental vessels in severe twin-twin transfusion syndrome. Obstet Gynecol. 06. 1990;75(6):1046-1053. [pmid: 2342732].
97 Chescheir NC. Maternal-fetal surgery: where are we and how did we get here?. Obstet Gynecol. 2009;113(3):717-731. [pmid: 19300340].
98 Moise KJ Jr, Dorman K, Lamvu G, et al. A randomized trial of amnioreduction versus septostomy in the treatment of twin-twin transfusion syndrome. Am J Obstet Gynecol. 09. 2005;193(3 Pt 1):701-707. [pmid: 16150263].