# Peer Reviewers

N. Scott Adzick, M.D.

Chief of Pedictric Surgery

Children’s Hospital of Philadelphia

Frank A. Chervenak, M.D.

Professor and Chairman, Department of Obstetrics and Gynecology

Director of Maternal-Fetal Medicine

Weill Medical College of Cornell University

Robyn Horsager Boehrer, M.D.

Associate Professor

University of Texas Southwestern Medical Center

Anthony Johnson, D.O.

Associate Professor

Baylor College of Medicine

Hanmin Lee, M.D.

Associate Professor of Surgery

Director, Fetal Treatment Center

University of California, San Francisco

Francois I. Luks, M.D., Ph.D.

Professor of Surgery, Pediatrics, Obstetrics and Gynecology

Division of Pediatric Surgery

Brown University

Laurence B. McCullough, Ph.D.

Associate Director for Education

Center for Medical Ethics and Health Policy

Baylor College of Medicine

Rubén Quintero, M.D.

Professor and Director, Division of Maternal-Fetal Medicine

Department of Obstetrics and Gynecology

University of Miami-Jackson Memorial Hospital Fetal Therapy Center

Catherine Y Spong, M.D.

Branch Chief

Pregnancy and Perinatology Branch

National Institute of Child Health and Human Development