# Ongoing Research

Study Name & Country | Outcomes | Maternal Criteria | Fetal Criteria
- RCT of Fetoscopic Endoluminal Tracheal Occlusion with a Balloon vs Expectant Mgmt during Pregnancy in Fetuses with Left-sided CDH and Moderate Pulmonary Hypoplasia; - Belgium | Primary: Occurrence of broncho-pulmonary dysplasia at 28 days of life Secondary:; - Survival at discharge,; - Survival free of bronchopulmonary dysplasia at 28 days of life | - Patients aged 18 years or more, and are able to consent ;; - Singleton pregnancy; - Accepting of randomization or to comply with return to FETO center; Exclusion:; - Maternal contraindication to fetoscopic surgery or severe medical condition in pregnancy;; - Technical limitations precluding fetoscopic surgery, such as severe maternal obesity, uterine fibroids or potentially others, not anticipated at the time of writing this protocol;; - Preterm labour, cervix shortened (<15 mm at randomization) or uterine anomaly strongly predisposing to preterm; - Diaphragmatic hernia | - Anatomically and chromosomally normal fetus;; - Left sided diaphragmatic hernia;; - Gestation at 32 wks plus 5 d ;; - O/E LHR 25–34.9% ;; - O/E LHR 35–44.9% (included) with intrathoracic liver herniation as determined by ultrasound or MRI
- Management of Myelomeningocele Study (MOMS); - US | Primary:; - Infant death,; - need for ventricular shunt by 1 year of life,; - Bayley Scales of Infant Development MDI and functional- anatomical level of lesion at 30 months of age; Secondary:; - Chiari II malformation,; - Neurodevelopmental status at 30 months; - Ambulation status 30 months, neuro-muscular defects 30 months; - Maternal psychological and reproductive functioning 30 months post-partum | Inclusion:; - US resident; - able to travel to study site for study; - Singleton pregnancy; Exclusion:; - Insulin-dependent pregestational diabetes; - Short or incompetent cervix or cervical cerclage,; - Placenta previa,; - BMI of 35 or more,; - previous spontaneous delivery prior to 37 weeks,; - HIV+; - Hepatitis B+; - Hepatitis C+; - Uterine anomaly | Inclusion:; - Myelomeningocele lesion that starts no higher than T1 and no lower than S1 with hindbrain herniation present; - Gestational age at randomization of 19 weeks 0 days to 25 weeks 6 days; - Normal karyotype
- Effect of Fetal Ovarian Cyst Aspiration to Prevent Torsion; - France | Primary:; - To avoid neonatal surgery; Secondary:; - U/S pattern of neonatal ovarian cyst; - maternal and fetal/neonatal safety of prenatal ovarian cyst aspiration | - Age 18–40 with singleton gestation | - Anechoic ovarian cyst (diameter at least 30mm)
- Selective Fetoscopic Laser Photo-coagulation versus Amnioreduction Clincial Trial; - US | Primary:; - Survival of donor twin at 30 days after birth and no treatment failure; - Survival of recipient twin at 30 days after birth and no treatment failure; Secondary:; - Survival times of each twin in utero or after birth; - Gestational age at delivery; - Placental insufficiency; - Cardiac outcome: echocardiographic evidence of cardiac compromise; - Neurologic outcome: evidence of brain injury preceding birth by MRI; - Postnatal comorbidity | Inclusion:; - 16+ years; - Diagnosis of TTTS prior to 22wks; - Randomized at 24 wks; - Both twins are alive; - Mono-di twin pregnancy; Exclusion:; - Contraindication to general surgery; - General anesthesia; - Uterine anomaly; - History of preterm labor; - Sonographic evidence of fetal CNS injury at time of entry; - Associated structural abnormalities | - Same sex with a thin intertwin membrane; - Oligo in the donor twin (deepest vertical pocket of </= 2 cm); - Decompressed bladder in donor twin not seen to fill during US exam (state II, III, or IV) unless Doppler velocimetry changes and/or echo changes are already present; - Polyhydramnios with deepest vertical pocket of >8 cm with or without Doppler or echocardiographic changes in the recipient twin (deepest vertical pocket of >6 if previous AR)
- Percutaneous Endoscopic Tracheal Plug/Unplug for CDH; - US | Primary:; - Neonatal survival at 90 days of life; Secondary:; - Fetal lung growth due to successful fetal tracheal occlusion/unocclus ion as determined by serial LHR measurements btw 26 and 34 wks gestation | Inclusion:; - 18+; - Meets psychosocial criteria; - Pre-authorization from third-party pay or for fetal intervention or ability to self-pay; Exclusion:; - Preterm labor; - Pre-eclampsia; - Uterine anomaly; - Unable/unwilling to stay in Providence, RI or San Francisco until removal of plug at 34 weeks | - Normal fetal echocardiogram; - Normal karyotype; - Fetal liver herniated into left hemithorax; - LHR 1.0 or less as calculated btw 24–26 week’s gestation; - Fetus is btw 26 and 28 weeks’ gestation; - Singleton pregnancy
- Selective IUGR with absent end-diastolic velocity in the umbilical artery in mono-di twin pregnancies: RCT of expectant mgmt versus laser therapy; - US | | Exclusion:; - Not able to make financial arrangements; - Unwilling to be randomized; - Unable/unwilling to be followed up | Inclusion:; - IUGR defined as sonographic estimated fetal weight at or below the 10th percentile for gestational age; - Single placenta; - Thin dividing membrane; - same gender; - Absent twin-peak sign; - Gestational age of 16–24 weeks; - Absent or reverse-end diastolic flow in the umbilical artery in the IUGR twin; - Absent or reverse-end diastolic flow in the umbilical artery in the IUGR twin; Exclusion:; - Not able to make financial arrangements; - Unwilling to be randomized; - Unable/unwilling to be followed up; - TTTS; - Major congenital anomalies; - Unbalanced chromosomal complement; - Ruptured or detached membranes; - Placental abruption; - Chorioamnionitis; - Triplets; - Active labor; - Placenta previa
- Effectiveness of Fetal Endotracheal Occlusion (FETO) in the Management of Severe Congenital Diaphragmatic Hernia; - US | - Neonatal survival rate after 90 days | Inclusion:; - Age 16–45 years; - Healthy enough to have surgery; - Must fully understand and accept the maternal and fetal risks involved; - Pre-authorization from third-party payor for fetal intervention, or ability to self-pay.; Exclusion:; - Contraindication to abdominal surgery or general anesthesia; - Allergy to latex; - Preterm labor, preeclampsia, or uterine anomaly (e.g., large fibroid tumor); - Family unable or refuse to stay in Denver for the duration of the tracheal occlusion period and for the duration of the pregnancy as medically necessary. | Inclusion:; - Confirmed diagnosis of CDH; - Normal fetal echocardiogram; - Normal karyotype; - Fetal liver herniated into the left hemithorax; - Lung-head ratio (LHR) is 1.0 or less, calculated between 24–26 weeks gestation; - Fetus is between 26 and 28 weeks gestation; - Singleton pregnancy; Exclusion:; - Failure to meet all inclusion criteria; - Other congenital anomalies detected on ultrasound
- Randomized Clinical Trial in Order to Assess the Effect of Fetoscopic Tracheal Balloon Occlusion on the Postnatal Disease Course in Neonates With Left Congenital Diaphragmatic Hernia; - Germany | Primary:; - Need for postnatal ECMO therapy in first 2 days of life; Secondary:; - Survival to discharge; - Maternal morbidity; - Fetal / Neonatal morbidity; - Premature preterm rupture of membranes; - Unintended preterm delivery; - Days in intensive care; - Days in hospital; - Oxygen dependency on discharge | Inclusion:; - Age 18–50; - Resident of European country carrying fetus with left diaphragmatic hernia; Exclusion:; - Any maternal disease or condition that would result in an increased risk to her health from the experimental procedure | Inclusion:; - Normal karyotype, no further severe anomalies on prenatal ultrasound study; - Fetal liver herniation into the chest; gestational age-related lung volume between 20–25% of normal as determined by magnetic resonance imaging between 30+0 − 34+0 weeks+days of gestation; Exclusion:; - Abnormal fetal karyotype, further severe fetal anomalies on prenatal ultrasound

## Additional Studies

Study title & location: | Study Description: | Project Start: | Project End:
- Mechanism of Vasopressin-Mediated Placental Vascular Resistance after Fetal Bypass; - US | Investigation of vasopressin and cardiac fetal surgery; selective V1 vasopressin receptor antagonism prevents increased placental vascular resistance and improves fetal gas exchange with fetal cardiac surgery and bypass | 1-Apr- 2009 | 31- Mar- 2011