# Excluded Studies

Full-text Article Exclusion Criteria Codes for Database

X-1: Not original research

X-3: Non-human study population

X-5: Ineligible study size (N <2)

X-6: Not related to selected conditions and/or not related to fetal surgery for selected conditions

X-7: Unable to obtain full-text

X-8: Case series of twin-twin transfusion syndrome

1 Crafoord C. Classics in thoracic surgery. Correction of aortic coarctation. Ann Thorac Surg. 1980;30(3):300-302. X-1, X-6. [pmid: 7000014].
2 Dor V, et al. Anomalous origin of left coronary artery from pulmonary artery. Evolution of right and left coronary circulation after surgical correction in four cases with delayed control. Thorac Cardiovasc Surg. 1980;28(1):51-56. X-6. [pmid: 6154337].
3 Doty DB, et al. Hypoplastic left heart syndrome: successful palliation with a new operation. J Thorac Cardiovasc Surg. 1980;80(1):148-152. X-5. [pmid: 6155567].
4 Fernhoff PM, Marion JP, Priest JH. Limitations of amniography in the prenatal diagnosis of spina bifida. Am J Med Genet. 1980;7(3):369-373. X-5. [pmid: 6162384].
5 Gomez R, et al. Management of patent ductus arteriosus in preterm babies. Ann Thorac Surg. 1980;29(5):459-463. X-6. [pmid: 7377887].
6 Harrison MR, Jester JA, Ross NA. Correction of congenital diaphragmatic hernia in utero. I. The model: intrathoracic balloon produces fatal pulmonary hypoplasia. Surgery. 1980;88(1):174-182. X-3, X-5. [pmid: 7385020].
7 Kirks DR, et al. Aneurysm of the ductus arteriosus in the neonate. AJR Am J Roentgenol. 1980;134(3):573-576. X-5, X-6. [pmid: 6766627].
8 Osathanondh R, et al. Ultrasonically guided transabdominal encephalocentesis. J Reprod Med. 1980;25(3):125-128. X-5, X-6. [pmid: 7001013].
9 Schifrin BS, Platt LD. Modified technique for monitoring fetal heart rate during intrauterine transfusion. Am J Obstet Gynecol. 1980;138(8):1220-1222. X-1. [pmid: 7446631].
10 Spirer Z. The role of the spleen in immunity and infection. Adv Pediatr. 1980;27:55-88. X-6. [pmid: 7194572].
11 Verma U, et al. Sinusoidal fetal heart rate patterns in severe Rh disease. Obstet Gynecol. 1980;55(5):666-669. X-6. [pmid: 7366927].
12 Barclay WR, et al. The ethics of in utero surgery. JAMA. 1981;246(14):1551-1552. X-1. [pmid: 6792373].
13 Birnholz JC, Frigoletto FD. Antenatal treatment of hydrocephalus. N Engl J Med. 1981;304(17):1021-1023. X-5. [pmid: 7207554].
14 Brambati B, Pardi G. The intraventricular conduction time of fetal heart in pregnancies complicated by rhesus haemolytic disease. Br J Obstet Gynaecol. 1981;88(12):1233-1240. X-6. [pmid: 7306477].
15 Canty TG, Leopold GR, Wolf DA. Maternal ultrasonography for the antenatal diagnosis of surgically significant neonatal anomalies. Ann Surg. 1981;194(3):353-365. X-6. [pmid: 6455975].
16 Clewell WH, et al. Placement of ventriculo-amniotic shunt for hydrocephalus in a fetus. N Engl J Med. 1981;305(16):955. X-1. [pmid: 7278901].
17 Cottrell AJ, Holden MP, Hunter S. Interrupted aortic arch type A associated with congenitally corrected transposition of great arteries and ventricular septal defect. Successful direct aortic anastomosis and pulmonary artery banding in an infant. Br Heart J. 1981;46(6):671-674. X-5. [pmid: 7317236].
18 Harrison MR, Golbus MS, Filly RA. Management of the fetus with a correctable congenital defect. JAMA. 1981;246(7):774-777. X-1. [pmid: 7253145].
19 Hodgen GD. Antenatal diagnosis and treatment of fetal skeletal malformations. With emphasis on in utero surgery for neural tube defects and limb bud regeneration. JAMA. 1981;246(10):1079-1083. X-1. [pmid: 6790732].
20 Pontius RG, et al. Illusions leading to surgical closure of the distal left pulmonary artery instead of the ductus arteriosus. J Thorac Cardiovasc Surg. 1981;82(1):107-113. X-6. [pmid: 7242118].
21 Williams TE Jr, Beach TP, Kilman JW. Pharmacological blood pressure reduction as an adjunct in the operation for patent ductus arteriosus. Ann Thorac Surg. 1981;31(1):90-91. X-6. [pmid: 7458478].
22 Ethics, future of fetal surgery uncertain. Ob Gyn News. 1982;17(11):3. 27. X-1.
23 Berkowitz RL, et al. Fetal urinary tract obstruction: what is the role of surgical intervention in utero. Am J Obstet Gynecol. 1982;144(4):367-375. X-1. [pmid: 7124856].
24 Canty TG, Wolf DA. Maternal ultrasound in neonatal surgery. Pediatr Ann. 1982;11(11):888-889. X-1. [pmid: 7155651].
25 Clewell WH, et al. A surgical approach to the treatment of fetal hydrocephalus. N Engl J Med. 1982;306(22):1320-1325. X-5. [pmid: 7070456].
26 Eggert LD, et al. Surgical treatment of patent ductus arteriosus in preterm infants. Four-year experience with ligation in the newborn intensive care unit. Pediatr Cardiol. 1982;2(1):15-18. X-6. [pmid: 7063423].
27 Friedman WF, Heiferman MF. Clinical problems of postoperative pulmonary vascular disease. Am J Cardiol. 1982;50(3):631-636. X-1, X-6. [pmid: 6214181].
28 Frigoletto FD Jr, Birnholz JC, Greene MF. Antenatal treatment of hydrocephalus by ventriculoamniotic shunting. JAMA. 1982;248(19):2496-2497. X-5. [pmid: 7131706].
29 Golbus MS, et al. In utero treatment of urinary tract obstruction. Am J Obstet Gynecol. 1982;142(4):383-388. X-5. [pmid: 7199255].
30 Graham D, et al. The role of sonography in the prenatal diagnosis and management of encephalocele. J Ultrasound Med. 1982;1(3):111-115. X-5. [pmid: 6152935].
31 Grunebaum AN, Sedlis A. Adenomatoid tumor of the uterus simulating interstitial pregnancy. Obstet Gynecol. 1982;59(6 Suppl):87S-88S. X-5, X-6. [pmid: 7088436].
32 Harrison MR, et al. Fetal surgery for congenital hydronephrosis. N Engl J Med. 1982;306(10):591-593. X-5. [pmid: 7057815].
33 Harrison MR, et al. Fetal surgical treatment. Pediatr Ann. 1982;11(11):896-899. X-6. [pmid: 7155652].
34 Hecht F, Hecht BK, O’Keeffe D. Sacrococcygeal teratoma: prenatal diagnosis with elevated alphafetoprotein and acetylcholinesterase in amniotic fluid. Prenat Diagn. 1982;2(3):229-231. X-5. [pmid: 6183656].
35 Karp LE. Fetal surgery. Am J Med Genet. 1982;13(4):357-358. X-1. [pmid: 7158635].
36 Kirkinen P, et al. Repeated transabdominal renocenteses in a case of fetal hydronephrotic kidney. Am J Obstet Gynecol. 1982;142(8):1049-1052. X-5. [pmid: 7072773].
37 Laks H. Advances in the repair of complex congenital heart disease. Pediatr Ann. 1982;11(11):926-927. X-6. [pmid: 7155656].
38 Levine AH, Imai PK. Intrauterine treatment of fetal hydronephrosis. AORN J. 1982;35(4):655-662. X-1. [pmid: 6917728].
39 Marsden DE, Chang AS, Shin KS. Decapitation and vaginal delivery for impacted transverse lie in late labour: reports of 4 cases. Aust N Z J Obstet Gynaecol. 1982;22(1):46-49. X-6. [pmid: 6954945].
40 Petres RE, Redwine FO, Cruikshank DP. Congenital bilateral chylothorax. Antepartum diagnosis and successful intrauterine surgical management. JAMA. 1982;248(11):1360-1361. X-5. [pmid: 7202055].
41 Rayburn WF. Surveillance techniques other than ultrasonography for detecting fetal malformations. J Reprod Med. 1982;27(9):565-568. X-1. [pmid: 6183424].
42 Robertson JA. The right to procreate and in utero fetal therapy. J Leg Med. 1982;3(3):333-366. X-1. [pmid: 6983547].
43 Roth A, et al. Patent ductus arteriosus in a 67-year-old woman: late diagnosis and surgical closure. Isr J Med Sci. 1982;18(9):952-954. X-5. [pmid: 7141856].
44 Ruddick W, Wilcox W. Operating on the fetus. Hastings Cent Rep. 1982;12(5):10-14. X-1. [pmid: 7174290].
45 Samberg I, et al. Early vaginal delivery of hydrocephalus after transabdominal encephalocentesis. Int J Gynaecol Obstet. 1982;20(3):227-229. X-5. [pmid: 6127251].
46 Vallancien G, et al. Percutaneous nephrostomy in utero. Urology. 1982;20(6):647-649. X-5. [pmid: 7179638].
47 Whittemore R, Hobbins JC, Engle MA. Pregnancy and its outcome in women with and without surgical treatment of congenital heart disease. Am J Cardiol. 1982;50(3):641-651. X-6. [pmid: 7113941].
48 In utero fetal surgery. Resolution 73 (I-81) council on scientific affairs. JAMA. 1983;250(11):1443-1444. X-1. [pmid: 6887469].
49 Alverson DC, et al. Effect of patent ductus arteriosus on left ventricular output in premature infants. J Pediatr. 1983;102(5):754-757. X-6. [pmid: 6842335].
50 Antsaklis A, et al. Prenatal diagnosis of hemoglobinopathies in twin pregnancies by double simultaneous fetoscopy. Prenat Diagn. 1983;3(1):21-27. X-6. [pmid: 6844262].
51 Bland RS, et al. Gonococcal ventriculitis associated with ventriculoamniotic shunt placement. Am J Obstet Gynecol. 1983;147(7):781-784. X-5. [pmid: 6418008].
52 Blane CE, et al. Nonobstructive fetal hydronephrosis: sonographic recognition and therapeutic implications. Radiology. 1983;147(1):95-99. X-6. [pmid: 6828770].
53 Cohen RA, Moskowitz PS, McCallum WD. Sonographic diagnosis of cystic adenomatoid malformation in-utero. Prenat Diagn. 1983;3(2):139-143. X-5. [pmid: 6622393].
54 Collins FS, Mahoney MJ. Hydrocephalus and abnormal digits after failed first-trimester prostaglandin abortion attempt. J Pediatr. 1983;102(4):620-621. X-5. [pmid: 6572713].
55 Daskalopoulos DA, et al. Fatal pulmonary artery banding in truncus arteriosus with anomalous origin of circumflex coronary artery from right pulmonary artery. Am J Cardiol. 1983;52(10):1363-1364. X-5, X-6. [pmid: 6650427].
56 Depp R, et al. Fetal surgery for hydrocephalus: successful in utero ventriculoamniotic shunt for Dandy-Walker syndrome. Obstet Gynecol. 1983;61(6):710-714. X-5. [pmid: 6843929].
57 DeVore GR, Dixon JA, Hobbins JC. Fetoscope-directed neodymium-YAG laser: a potential tool for fetal surgery. Am J Obstet Gynecol. 1983;145(3):379-380. X-3, X-5, X-6. [pmid: 6824028].
58 Donovan P. When does personhood begin. Fam Plann Perspect. 1983;15(1):40-44. X-1. [pmid: 6680701].
59 Edwards WR. A fetal sacrococcygeal tumor obstructing labor after attempted home confinement. Obstet Gynecol. 1983;61(3 Suppl):19S-20S. X-5. [pmid: 6823390].
60 Elias S, Annas GJ. Perspectives on fetal surgery. Am J Obstet Gynecol. 1983;145(7):807-812. X-1, X-3. [pmid: 6682291].
61 Farkas A, Eidelman AI, Gale R. Transient perinatal urinary retention: a cautionary note for the fetal surgeon. Am J Obstet Gynecol. 1983;147(4):461-462. X-5. [pmid: 6624816].
62 Fletcher JC. Emerging ethical issues in fetal therapy. Prog Clin Biol Res. 1983;128:293-318. X-1. [pmid: 6579558].
63 Gilmore A. Is the fetus a patient?. Can Med Assoc J. 1475. 1983;128(12):1472-1476. X-1. [pmid: 6850473].
64 Goldman EB. Fetal versus maternal rights: who is the patient. Mich Hosp. 1983;19(4):23-25. X-1. [pmid: 10259175].
65 Hertogs K, et al. The safety of fetoscopy: (I). Effect of umbilical vessel puncture on the fetal heart rate and cord histology. Prenat Diagn. 1983;3(2):91-96. X-6. [pmid: 6622401].
66 Johnson ML, et al. Fetal hydrocephalus: diagnosis and management. Semin Perinatol. 1983;7(2):83-89. X-1. [pmid: 6635672].
67 Labbe R, et al. Fetal brain transplant: reduction of cognitive deficits in rats with frontal cortex lesions. Science. 1983;221(4609):470-472. X-3. [pmid: 6683427].
68 Lenow JL. The fetus as a patient: emerging rights as a person. Am J Law Med. 1983;9(1):1-29. X-1. [pmid: 6638018].
69 Mintz MC, Mennuti M, Fishman M. Prenatal aspiration of sacrococcygeal teratoma. AJR Am J Roentgenol. 1983;141(2):367-368. X-5. [pmid: 6603135].
70 Norwood WI, Lang P, Hansen DD. Physiologic repair of aortic atresia-hypoplastic left heart syndrome. N Engl J Med. 1983;308(1):23-26. X-5, X-6. [pmid: 6847920].
71 Onitsuka T, et al. Echographic detection and successful excision of pulmonary cyst in a fetus. Jpn J Surg. 1983;13(3):254-257. X-5. [pmid: 6632398].
72 Redwine FO, Petres RE, Cruikshank DP. Reversal of polyhydramnios by drainage of a fetal renal cyst. A case report. J Reprod Med. 1983;28(6):421-423. X-5. [pmid: 6350578].
73 Schaaps JP, Thoumsin H, Lambotte R. Intrauterine unilateral nephrostomy. Am J Obstet Gynecol. 1983;146(1):105-106. X-5. [pmid: 6846410].
74 Soper RT. President’s address: the Pandora’s box of antenatal surgery. Am Surg. 1983;49(6):285-289. X-1. [pmid: 6859667].
75 Vintzileos AM, et al. Unilateral fetal hydronephrosis: successful in utero surgical management. Am J Obstet Gynecol. 1983;145(7):885-886. X-5. [pmid: 6837667].
76 Weinberg SR. A maternal duty to protect fetal health. Indiana Law J. 1983;58(3):531-546. X-1. [pmid: 16211746].
77 Bannister CM. Fetal neurosurgery—a new challenge on the horizon. Dev Med Child Neurol. 1984;26(6):827-830. X-1. [pmid: 6542889].
78 Boehm FH. Management of the unanticipated neural tube defect in late pregnancy. Clin Obstet Gynecol. 1984;27(1):78-83. X-1. [pmid: 6200263].
79 Burakovsky VI, Falkovsky GE, Ivanitsky AV. Surgical repair of truncus arteriosus. Pediatr Cardiol. 1984;5(2):111-114. X-6. [pmid: 6473120].
80 Chervenak FA, Romero R. Is there a role for fetal cephalocentesis in modern obstetrics. Am J Perinatol. 1984;1(2):170-173. X-1. [pmid: 6394011].
81 Crowley P, O’Herlihy C, Boylan P. The value of ultrasound measurement of amniotic fluid volume in the management of prolonged pregnancies. Br J Obstet Gynaecol. 1984;91(5):444-448. X-6. [pmid: 6722063].
82 Dao AH, Netsky MG. Human tails and pseudotails. Hum Pathol. 1984;15(5):449-453. X-5, X-6. [pmid: 6373560].
83 Dunn P. Surgery for the unborn: a nurse’s own story. Nurs Life. 1984;4(5):19-21. X-1. [pmid: 6566023].
84 Golladay ES, Mollitt DL. Surgically correctable fetal hydrops. J Pediatr Surg. 1984;19(1):59-62. X-6. [pmid: 6366180].
85 Kindregan C. Compulsory fetal surgery: an issue for the future, Report Hum Reprod Law 1984;Reports: 111–112. X-1.
86 Kramer SA, Kelalis PP. Approach to the foetus with congenital hydronephrosis. Ann Acad Med Singapore. 1984;13(4):565-570. X-1. [pmid: 6397101].
87 Lowe TW, et al. Sinusoidal fetal heart rate pattern after intrauterine transfusion. Obstet Gynecol. 1984;64(3 Suppl):21S-25S. X-1. [pmid: 6472745].
88 Matthews AL, Costello AJ, Scott JA. The fetus as a patient: some preliminary data from the first year of a fetal medicine and surgery program. Birth Defects Orig Artic Ser. 1984;20(6):192-196. X-6. [pmid: 6535596].
89 McFadyen IR. Obstruction of the fetal urinary tract: a role for surgical intervention in utero?. Br Med J (Clin Res Ed). 1984;288(6415):459-462. X-6.
90 Nicolini U, Hertogs K, Rodeck CH. Sinusoidal rhythm caused by fetal hemorrhage during fetoscopy. J Perinat Med. 1984;12(1):39-42. X-5. [pmid: 6726594].
91 Puri P, Gorman F. Lethal nonpulmonary anomalies associated with congenital diaphragmatic hernia: implications for early intrauterine surgery. J Pediatr Surg. 1984;19(1):29-32. X-6. [pmid: 6699760].
92 Reedy NJ, Ford KL, Depp R. Intrauterine fetal surgery: a nursing challenge. JOGN Nurs. 1984;13(5):291-295. X-1. [pmid: 6566813].
93 Rudeen RL, Elliott JP. In utero management of fetal urinary tract obstruction: case report. Mil Med. 1984;149(2):87-88. X-5. [pmid: 6427664].
94 Seeds JW, et al. Hydramnios and maternal renal failure: relief with fetal therapy. Obstet Gynecol. 1984;64(3 Suppl):26S-29S. X-5. [pmid: 6382080].
95 Seeds JW, et al. Recurrent idiopathic fetal hydrops: results of prenatal therapy. Obstet Gynecol. 1984;64(3 Suppl):30S-33S. X-5. [pmid: 6382081].
96 Shalev E, et al. External bladder—amniotic fluid shunt for fetal urinary tract obstruction. Obstet Gynecol. 1984;63(3 Suppl):31S-34S. X-5. [pmid: 6538325].
97 Spicer RL, et al. Repair of truncus arteriosus in neonates with the use of a valveless conduit. Circulation. 1984;70(3 Pt 2):I26-I29. X-6. [pmid: 6744567].
98 Spirnak JP, et al. Incidental fetal hydronephrosis: clinical implication. Urology. 1984;24(1):105-108. X-6. [pmid: 6539995].
99 Weissman MN, Green BA, Morse B. In-utero gunshot wound to the head. Use of intraoperative ultrasonography for localization of an intracerebral projectile. Surg Neurol. 1984;21(4):347-350. X-5, X-6. [pmid: 6701767].
100 Williamson RA, et al. Heterogeneity of prenatal onset hydrocephalus: management and counseling implications. Am J Med Genet. 1984;17(2):497-508. X-6. [pmid: 6702900].
101 Adzick NS, et al. Diaphragmatic hernia in the fetus: prenatal diagnosis and outcome in 94 cases. J Pediatr Surg. 1985;20(4):357-361. X-6. [pmid: 4045660].
102 Avni EF, Rodesch F, Schulman CC. Fetal uropathies: diagnostic pitfalls and management. J Urol. 1985;134(5):921-925. X-6. [pmid: 3903217].
103 Bowman JM. Alloimmunization in twin pregnancies. Am J Obstet Gynecol. 1985;153(1):7-13. X-6. [pmid: 3929607].
104 Chervenak FA, et al. Diagnosis and management of fetal teratomas. Obstet Gynecol. 1985;66(5):666-671. X-6. [pmid: 3903582].
105 Engelhardt HT Jr. Current controversies in obstetrics: wrongful life and forced fetal surgical procedures. Am J Obstet Gynecol. 1985;151(3):313-318. X-1. [pmid: 3970098].
106 Fitzsimons RB, Keohane C, Galvin J. Prune belly syndrome with ultrasound demonstration of reduction of megacystis in utero. Br J Radiol. 1985;58(688):374-376. X-5, X-6. [pmid: 3904900].
107 Gaffney SE. Intrauterine fetal surgery: the ramifications for nurses. MCN Am J Matern Child Nurs. 1985;10(4):250-254. X-1. [pmid: 3925283].
108 Glick PL, et al. Management of the fetus with congenital hydronephrosis II: Prognostic criteria and selection for treatment. J Pediatr Surg. 1985;20(4):376-387. X-6. [pmid: 3900327].
109 Harrison MR, et al. Fetal diaphragmatic hernia: fetal but fixable. Semin Perinatol. 1985;9(2):103-112. X-1. [pmid: 3898385].
110 Holzgreve W, et al. Sonographic demonstration of fetal sacrococcygeal teratoma. Prenat Diagn. 1985;5(4):245-257. X-6. [pmid: 3900972].
111 Inturrisi M, Perry SE, May KA. Fetal surgery for congenital hydronephrosis. J Obstet Gynecol Neonatal Nurs. 1985;14(4):271-276. X-1.
112 Kaufmann CL, Williams PR. Fetal surgery: the social implications of medical and surgical treatment of the unborn child. Women Health. 1985;10(1):25-37. X-1. [pmid: 3984357].
113 Kirkinen P, Jouppila P. Perinatal aspects of pregnancy complicated by fetal ovarian cyst. J Perinat Med. 1985;13(5):245-251. X-6. [pmid: 3910792].
114 Moniz CF, et al. Normal reference ranges for biochemical substances relating to renal, hepatic, and bone function in fetal and maternal plasma throughout pregnancy. J Clin Pathol. 1985;38(4):468-472. X-6. [pmid: 3988961].
115 Murray TH. Ethical issues in fetal surgery. Bull Am Coll Surg. 1985;70(6):6-10. X-1. [pmid: 10271259].
116 Nakayama DK, et al. Prenatal diagnosis and natural history of the fetus with a congenital diaphragmatic hernia: initial clinical experience. J Pediatr Surg. 1985;20(2):118-124. X-1, X-5, X-6. [pmid: 3891952].
117 Ott DA, et al. Surgical treatment for the type II and III truncus: complete division of the truncal root with primary repair using absorbable suture. Ann Thorac Surg. 1985;40(2):201-204. X-6. [pmid: 3896174].
118 Phelan JP, et al. The role of external version in the intrapartum management of the transverse lie presentation. Am J Obstet Gynecol. 1985;151(6):724-726. X-6. [pmid: 3976779].
119 Platt LD, DeVore GR. Modification of fetal intraventricular amniotic shunt. Am J Obstet Gynecol. 1985;152(8):1044-1045. X-3, X-5, X-6. [pmid: 4025451].
120 Reynolds JE, et al. Fetal hydrocephalus: a case of ventricular-amniotic shunting. South Med J. 1985;78(2):203-204. X-5. [pmid: 3975718].
121 Saunders RL, et al. A cranial nail for fetal shunting. Childs Nerv Syst. 1985;1(3):185-187. X-5. [pmid: 4042109].
122 Smith RJ. Preventive surgery for congenital deformities of the hand. Hand Clin. 1985;1(3):373-382. X-6. [pmid: 3868641].
123 Stolar CJ, Altman RP. Research in pediatric surgery. World J Surg. 1985;9(2):321-328. X-1. [pmid: 3993063].
124 Appelman Z, Golbus MS. The management of fetal urinary tract obstruction. Clin Obstet Gynecol. 1986;29(3):483-489. X-1. [pmid: 3757330].
125 Blank RH. Emerging notions of women’s rights and responsibilities during gestation. J Leg Med. 1986;7(4):441-469. X-1. [pmid: 3492583].
126 Chiaramonte RM, et al. Implications of hydronephrosis in the newborn with myelodysplasia. J Urol. 1986;136(2):427-429. X-6. [pmid: 3735509].
127 Edwards MS. An evaluation of the in utero neurosurgical treatment of ventriculomegaly. Clin Neurosurg. 1986;33:347-357. X-3. [pmid: 3098489].
128 Flake AW, et al. Fetal sacrococcygeal teratoma. J Pediatr Surg. 1986;21(7):563-566. X-6. [pmid: 3525800].
129 Flake AW, et al. Ureteropelvic junction obstruction in the fetus. J Pediatr Surg. 1986;21(12):1058-1063. X-6. [pmid: 3540267].
130 Fletcher JC. Drawing moral lines in fetal therapy. Clin Obstet Gynecol. 1986;29(3):595-602. X-1. [pmid: 3757337].
131 Friedman M. Factors influencing parathyroid allotransplantation in rats. Laryngoscope. 1986;96(9 Pt 2 Suppl 39):1-16. X-3. [pmid: 3747700].
132 Gregorios JB, et al. Spinal cord tumors presenting with neural tube defects. Neurosurgery. 1986;19(6):962-966. X-6. [pmid: 3808243].
133 Hardy K. Prospects for fetal surgery. Aust N Z J Surg. 1986;56(4):295-297. X-1. [pmid: 3459439].
134 Harman CR. Bioethical issues in perinatology—is the future now. Fetal Ther. 1986;1(4):217-222. X-1. [pmid: 3454534].
135 Haroutunian V, et al. Animal models of Alzheimer’s disease: behavior, pharmacology, transplants. Can J Neurol Sci. 1986;13(4 Suppl):385-393. X-3. [pmid: 2878711].
136 Harrison MR, et al. Fetal diaphragmatic hernia: pathophysiology, natural history, and outcome. Clin Obstet Gynecol. 1986;29(3):490-501. X-6. [pmid: 3757331].
137 Holschneider AM, Baumgartner M, Mascott C. Consequences of antenatal diagnosis for pediatric surgery. Prog Pediatr Surg. 1986;19:184-196. X-6. [pmid: 3081957].
138 Lundell BP, Sonesson SE, Cotton RB. Ductus closure in preterm infants. Effects on cerebral hemodynamics. Acta Paediatr Scand Suppl. 1986;329:140-147. X-6. [pmid: 3296647].
139 Manning FA. International Fetal Surgery Registry: 1985 update. Clin Obstet Gynecol. 1986;29(3):551-557. X-1. [pmid: 3757335].
140 Marek J, Dvoracek J. Renal changes in vesicoureteral reflux—human reflux nephropathy. Zentralbl Allg Pathol. 1986;132(5–6):413-422. X-6. [pmid: 3564729].
141 Michejda M, Pringle K. Fascination with the mystery of new life in utero. Fetal Ther. 1986;1(1):3-7. X-1. [pmid: 3505406].
142 Michejda M, Queenan JT, McCullough D. Present status of intrauterine treatment of hydrocephalus and its future. Am J Obstet Gynecol. 1986;155(4):873-882. X-3. [pmid: 3766644].
143 Nicolaides KH, Rodeck CH, Gosden CM. Rapid karyotyping in non-lethal fetal malformations. Lancet. 1986;1(8476):283-287. X-6. [pmid: 2868161].
144 Paine LL, Payton RG, Johnson TR. Auscultated fetal heart rate accelerations. Part I. Accuracy and documentation. J Nurse Midwifery. 1986;31(2):68-72. X-1. [pmid: 3633984].
145 Perry SE, Inturrisi M, Filly RA. Meeting the challenge of fetal surgery. Dimens Crit Care Nurs. 1986;5(4):196-205. X-1. [pmid: 3637149].
146 Pober BR, Greene MF, Holmes LB. Complexities of intraventricular abnormalities. J Pediatr. 1986;108(4):545-551. X-6. [pmid: 3514828].
147 Pretorius DH, et al. Diagnosis of brain neuropathology in utero. Neuroradiology. 1986;28(5–6):386-397. X-6. [pmid: 3540704].
148 Pringle KC. Fetal surgery: it has a past, has it a future. Fetal Ther. 1986;1(1):23-31. X-1. [pmid: 3333205].
149 Robertson JA. Legal issues in prenatal therapy. Clin Obstet Gynecol. 1986;29(3):603-611. X-1. [pmid: 3757338].
150 Seeds JW, Jones FD. Lipomyelomeningocele: prenatal diagnosis and management. Obstet Gynecol. 1986;67(3 Suppl):34S-37S. X-5. [pmid: 3511425].
151 Stauffer UG. Management of prenatally diagnosed congenital malformations—actual problems and the importance of an interdisciplinary team approach. Prog Pediatr Surg. 1986;19:127-142. X-5. [pmid: 3081952].
152 Weiner C, et al. Antenatal diagnosis and palliative treatment of nonimmune hydrops fetalis secondary to pulmonary extralobar sequestration. Obstet Gynecol. 1986;68(2):275-280. X-5. [pmid: 2426639].
153 Weiner C, et al. In utero bladder diversion—problems with patient selection. Fetal Ther. 1986;1(4):196-202. X-5. [pmid: 3331502].
154 Chayen B, Rifkin MD. Cephalocentesis. Guidance with an endovaginal probe and endovaginal needle placement. J Ultrasound Med. 1987;6(4):221-223. X-5. [pmid: 3295290].
155 Clark SL, et al. Successful fetal therapy for cystic adenomatoid malformation associated with second-trimester hydrops. Am J Obstet Gynecol. 1987;157(2):294-295. X-5. [pmid: 3303933].
156 Colodny AH. Antenatal diagnosis and management of urinary abnormalities. Pediatr Clin North Am. 1987;34(5):1365-1381. X-1. [pmid: 3309853].
157 Gross TL, et al. Shoulder dystocia: a fetal-physician risk. Am J Obstet Gynecol. 1987;156(6):1408-1418. X-6. [pmid: 3591856].
158 Harrison MR, et al. Fetal hydronephrosis: selection and surgical repair. J Pediatr Surg. 1987;22(6):556-558. X-5. [pmid: 3302200].
159 Holzgreve W, et al. Experience with 8 cases of prenatally diagnosed sacrococcygeal teratomas. Fetal Ther. 1987;2(2):88-94. X-6. [pmid: 3332743].
160 Kiwanuka AI, Moore WM. The changing incidence of caesarean section in the health district of Central Manchester. Br J Obstet Gynaecol. 1987;94(5):440-444. X-6. [pmid: 3580327].
161 Langer JC, Harrison MR, Adzick NS. Congenital diaphragmatic hernia: current controversies in prenatal and postnatal management. Fetal Ther. 1987;2(4):209-215. X-5. [pmid: 3509195].
162 Manning FA. Fetal surgery for obstructive uropathy: rational considerations. Am J Kidney Dis. 1987;10(4):259-267. X-1, X-3. [pmid: 3310616].
163 Murray TH. Moral obligations to the not-yet born: the fetus as patient. Clin Perinatol. 1987;14(2):329-343. X-1. [pmid: 3595055].
164 Nakamura Y, et al. Nonimmunologic hydrops fetalis: a clinicopathological study of 50 autopsy cases. Pediatr Pathol. 1987;7(1):19-30. X-6. [pmid: 3601817].
165 Nicolini U, Rodeck CH, Fisk NM. Shunt treatment for fetal obstructive uropathy. Lancet. 1987;2(8571):1338-1339. X-5, X-6. [pmid: 2890942].
166 Rauscher K. Fetal surgery: a developing legal dilemma. St Louis Univ Law J. 1987;31(3):775-795. X-1. [pmid: 11658987].
167 Redwine FO. Fetal medicine and surgery. Med Sect Proc. 1987:69-75. X-1.
168 Shurtleff DB, et al. The outcome of pregnancies diagnosed as having a fetus with meningomyelocele. Z Kinderchir. 1987;42(Suppl 1):50-52. X-6. [pmid: 3324542].
169 Silver RK, Huff RW. Intrapartum management of the fetus with idiopathic hydrocephalus. Am J Perinatol. 1987;4(1):16-19. X-5. [pmid: 3539132].
170 Thomassen-Brepols LJ. Psychological implications of fetal diagnosis and therapy. Fetal Ther. 1987;2(3):169-174. X-1. [pmid: 3508344].
171 Varga DA, et al. Vaginal delivery impeded by a large fetal sacrococcygeal teratoma: anesthetic considerations. Anesth Analg. 1987;66(12):1325-1327. X-6. [pmid: 3688507].
172 Wilkins IA, et al. The nonpredictive value of fetal urinary electrolytes: preliminary report of outcomes and correlations with pathologic diagnosis. Am J Obstet Gynecol. 1987;157(3):694-698. X-5. [pmid: 3307426].
173 Wilkinson LG, et al. Surgical problems in the fetus: a multidisciplinary approach. Am J Surg. 1987;154(6):685-687. X-1. [pmid: 3425818].
174 Ardinger HH, et al. Verification of the fetal valproate syndrome phenotype. Am J Med Genet. 1988;29(1):171-185. X-6. [pmid: 3125743].
175 Ash KM, Mibashan RS, Nicolaides KH. Diagnosis and treatment of feto-maternal hemorrhage in a fetus with homozygous von Willebrand’s disease. Fetal Ther. 1988;3(4):189-191. X-5, X-6. [pmid: 3273839].
176 Blott M, Nicolaides KH, Greenough A. Postnatal respiratory function after chronic drainage of fetal pulmonary cyst. Am J Obstet Gynecol. 1988;159(4):858-859. X-5, X-6. [pmid: 3177537].
177 Cassady G. Relation between persistent patency of the ductus arteriosus and retinopathy of prematurity. Birth Defects Orig Artic Ser. 1988;24(1):53-65. X-6. [pmid: 3179420].
178 Clewell WH. Congenital hydrocephalus: treatment in utero. Fetal Ther. 1988;3(1–2):89-97. X-1. [pmid: 3257071].
179 Fine C, Adzick NS, Doubilet PM. Decreasing size of a congenital cystic adenomatoid malformation in utero. J Ultrasound Med. 1988;7(7):405-408. X-5. [pmid: 3043020].
180 Fuglestad SJ, et al. Surgical pathology of the truncal valve: a study of 12 cases. Am J Cardiovasc Pathol. 1988;2(1):39-47. X-6. [pmid: 3207487].
181 Hage ML, et al. Changing rates of cesarean delivery: the Duke experience, 1978–1986. Obstet Gynecol. 1988;72(1):98-101. X-6. [pmid: 3380513].
182 Johnson JW, et al. Abdominal rescue after incomplete delivery secondary to large fetal sacrococcygeal teratoma. Obstet Gynecol. 1988;71(6 Pt 2):981-984. X-6. [pmid: 3374921].
183 Johnston PW. The diagnostic value of alpha-fetoprotein in an infant with sacrococcygeal teratoma. J Pediatr Surg. 1988;23(9):862-863. X-5, X-6. [pmid: 2460607].
184 McKone RC, Weesner KM. Determination of the time of closure of the ductus arteriosus in severely ill premature infants. Clin Pediatr (Phila). 1988;27(3):135-139. X-6. [pmid: 3342596].
185 Pendl G. Symposium on ethics and morals related to antenatal treatment of pediatric neurosurgical disorders. Treatment of fetuses in utero—an opinion from central Europe. Childs Nerv Syst. 1988;4(3):158-160. X-1. [pmid: 3396023].
186 Purkiss S, Brereton RJ, Wright VM. Surgical emergencies after prenatal treatment for intra-abdominal abnormality. Lancet. 1988;1(8580):289-290. X-5, X-6. [pmid: 2893094].
187 Raimondi AJ. Shunts, indications, problems, and characteristics. Childs Nerv Syst. 1988;4(6):321-324. X-1. [pmid: 3245941].
188 Rodeck CH, et al. Long-term in utero drainage of fetal hydrothorax. N Engl J Med. 1988;319(17):1135-1138. X-6. [pmid: 3173443].
189 Saltzman DH, Adzick NS, Benacerraf BR. Fetal cystic adenomatoid malformation of the lung: apparent improvement in utero. Obstet Gynecol. 1988;71(6 Pt 2):1000-1002. X-6. [pmid: 3287247].
190 Urig MA, et al. Twin-twin transfusion syndrome: the surgical removal of one twin as a treatment option. Fetal Ther. 1988;3(4):185-188. X-5. [pmid: 3273838].
191 Westgren M, Selbing A, Stangenberg M. Fetal intracardiac transfusions in patients with severe rhesus isoimmunisation. Br Med J (Clin Res Ed). 1988;296(6626):885-886. X-6.
192 Baisden CE, et al. Ductus diverticulum aneurysm and coronary stenosis: repair using circulatory arrest. Ann Thorac Surg. 1989;48(3):432-433. X-5. [pmid: 2774734].
193 Beluffi G, et al. Congenital cystic adenomatoid malformation of the lung. Presentation of 16 cases. Rofo. 1989;150(5):523-530. X-6. [pmid: 2541476].
194 Bernaschek G, et al. Intrauterine treatment of a fetal pulmonary cyst by chorioamniotic shunt. Arch Gynecol Obstet. 1989;244(2):129-132. X-5, X-6. [pmid: 2712598].
195 Cassady G, et al. A randomized, controlled trial of very early prophylactic ligation of the ductus arteriosus in babies who weighed 1000 g or less at birth. N Engl J Med. 1989;320(23):1511-1516. X-6. [pmid: 2498657].
196 Copel JA, et al. Fetal cardiac output in the isoimmunized pregnancy: a pulsed Doppler-echocardiographic study of patients undergoing intravascular intrauterine transfusion. Am J Obstet Gynecol. 1989;161(2):361-365. X-6. [pmid: 2504042].
197 Davies RP, et al. Ultrasonic detection of subdiaphragmatic pulmonary sequestration in utero and postnatal diagnosis by fine-needle aspiration biopsy. J Ultrasound Med. 1989;8(1):47-49. X-6. [pmid: 2644442].
198 Drugan A, et al. The natural history of prenatally diagnosed cerebral ventriculomegaly. JAMA. 1989;261(12):1785-1788. X-6. [pmid: 2645455].
199 Drugan A, et al. First trimester diagnosis and early in utero treatment of obstructive uropathy. Acta Obstet Gynecol Scand. 1989;68(7):645-649. X-5. [pmid: 2698590].
200 Fadel HE. Antenatal diagnosis of fetal intracranial anomalies. J Child Neurol. 1989;4(Suppl):S107-S112. X-1. [pmid: 2681372].
201 Galligan BR, et al. Preparation of packed red cells suitable for intravascular transfusion in utero. Transfusion. 1989;29(2):179-181. X-6. [pmid: 2919428].
202 Gembruch U, et al. Fetal complete heart block: antenatal diagnosis, significance and management. Eur J Obstet Gynecol Reprod Biol. 1989;31(1):9-22. X-6. [pmid: 2653898].
203 Hutson J. Fetal surgery at the crossroads. Indian J Pediatr. 1989;56(5):570-572. X-1. [pmid: 2698866].
204 Johnsen D, Wilder MJ. Webster and women’s equality. Am J Law Med. 1989;15(2–3):178-184. X-1. [pmid: 2603859].
205 Johnson MD, et al. Fetal surgery and general anesthesia: a case report and review. J Clin Anesth. 1989;1(5):363-367. X-5, X-6. [pmid: 2697242].
206 Langer JC, et al. Gastrointestinal tract obstruction in the fetus. Arch Surg. 1989;124(10):1183-1186. discussion 1187. X-6. [pmid: 2679491].
207 Langer JC, et al. Fetal hydrops and death from sacrococcygeal teratoma: rationale for fetal surgery. Am J Obstet Gynecol. 1989;160(5 Pt 1):1145-1150. X-5. [pmid: 2658603].
208 Lodeiro JG, et al. Antenatal diagnosis of epignathus with neonatal survival. A case report. J Reprod Med. 1989;34(12):997-999. X-5. [pmid: 2695649].
209 Norris MC, Joseph J, Leighton BL. Anesthesia for perinatal surgery. Am J Perinatol. 1989;6(1):39-40. X-5. [pmid: 2910316].
210 Nugent CE, Hayashi RH, Rubin J. Prenatal treatment of type I congenital cystic adenomatoid malformation by intrauterine fetal thoracentesis. J Clin Ultrasound. 1989;17(9):675-677. X-5. [pmid: 2514205].
211 Ouimet A, Russo P. Fetus in fetu or not. J Pediatr Surg. 1989;24(9):926-927. X-5. [pmid: 2778588].
212 Robie GF, Payne GG Jr, Morgan MA. Selective delivery of an acardiac, acephalic twin. N Engl J Med. 1989;320(8):512-513. X-5, X-6. [pmid: 2915653].
213 Rosner F, et al. Fetal therapy and surgery. Fetal rights versus maternal obligations. N Y State J Med. 1989;89(2):80-84. X-1. [pmid: 2710438].
214 Rostain AL, Bhutani VK. Ethical dilemmas of neonatal--perinatal surgery. Clin Perinatol. 1989;16(1):275-302. X-1. [pmid: 2656064].
215 Sano K. Quo vadis, neurochirurgia paediatrica. Childs Nerv Syst. 1989;5(1):3-8. X-1. [pmid: 2649241].
216 Schmidt KG, et al. High-output cardiac failure in fetuses with large sacrococcygeal teratoma: diagnosis by echocardiography and Doppler ultrasound. J Pediatr. 1989;114(6):1023-1028. X-6. [pmid: 2656957].
217 Sepulveda WH. Prenatal sonographic diagnosis of congenital sacrococcygeal teratoma and management. J Perinat Med. 1989;17(2):93-97. X-5, X-6. [pmid: 2681670].
218 Touraine JL. New strategies in the treatment of immunological and other inherited diseases: allogeneic stem cells transplantation. Bone Marrow Transplant. 1989;4(Suppl 4):139-141. X-6. [pmid: 2576388].
219 Barbero-Marcial M, et al. A technique for correction of truncus arteriosus types I and II without extracardiac conduits. J Thorac Cardiovasc Surg. 1990;99(2):364-369. X-6. [pmid: 2299877].
220 Dado DV, Kernahan DA, Gianopoulos JG. Intrauterine repair of cleft lip: what’s involved. Plast Reconstr Surg. 1990;85(3):461-465. discussion 466–467. X-6. [pmid: 2305000].
221 Fischer RL, et al. Chronic, massive fetomaternal hemorrhage treated with repeated fetal intravascular transfusions. Am J Obstet Gynecol. 1990;162(1):203-204. X-5. [pmid: 2301494].
222 Fisk NM, et al. Fetofetal transfusion syndrome: do the neonatal criteria apply in utero. Arch Dis Child. 1990;65(7 Spec No):657-661. X-6. [pmid: 1696801].
223 Giorlandino C, et al. Successful intrauterine therapy of a large fetal ovarian cyst. Prenat Diagn. 1990;10(7):473-475. X-5. [pmid: 2235907].
224 Goldstein P, et al. Ventriculoamniotic shunt for treatment of hydrocephalus in one of twins: medical, ethical and legal considerations. Fetal Diagn Ther. 1990;5(2):84-91. X-5. [pmid: 2130834].
225 Grannum PA, Copel JA. Invasive fetal procedures. Radiol Clin North Am. 1990;28(1):217-226. X-1. [pmid: 2404303].
226 Gruenewald SM, et al. Diagnosis and treatment of antenatal uropathies. J Paediatr Child Health. 1990;26(3):142-147. X-6. [pmid: 2206613].
227 Harrison MR. Fetal surgery. West J Med. 1990;153(6):648. X-1. [pmid: 2293474].
228 Harrison MR, et al. Successful repair in utero of a fetal diaphragmatic hernia after removal of herniated viscera from the left thorax. N Engl J Med. 1990;322(22):1582-1584. X-5. [pmid: 2336088].
229 Heffez DS, et al. The paralysis associated with myelomeningocele: clinical and experimental data implicating a preventable spinal cord injury. Neurosurgery. 1990;26(6):987-992. X-3. [pmid: 2362676].
230 Hogge WA, et al. Diagnosis and management of prenatally detected myelomeningocele: a preliminary report. Am J Obstet Gynecol. 1990;163(3):1061-1064. discussion 1064–5. X-6. [pmid: 2206057].
231 Leon Sosa RR, Moore PJ. Sacrococcygeal teratomas in the fetus and newborn. Int J Gynaecol Obstet. 1990;32(1):61-66. X-6. [pmid: 1971238].
232 Naruse I, Kameyama Y. Fetal laser surgery in genetic polydactyly mice. Teratology. 1990;41(6):731-735. X-3. [pmid: 2191460].
233 Oi SZ, et al. Factors affecting prognosis of intrauterine hydrocephalus diagnosed in the third trimester--computerized data analysis on controversies in fetal surgery. Neurol Med Chir (Tokyo). 1990;30(7):456-461. X-6. [pmid: 1701855].
234 Rizzo G, et al. Effects of intravascular fetal blood transfusion on fetal intracardiac Doppler velocity waveforms. Am J Obstet Gynecol. 1990;163(4 Pt 1):1231-1238. X-6. [pmid: 2220934].
235 Sherer DM, et al. Prenatal sonographic diagnosis and subsequent management of fetal adnexal torsion. J Ultrasound Med. 1990;9(3):161-163. X-5. [pmid: 2407863].
236 Silverman NH, Schmidt KG. Ventricular volume overload in the human fetus: observations from fetal echocardiography. J Am Soc Echocardiogr. 1990;3(1):20-29. X-6. [pmid: 2310588].
237 Steinhardt G, et al. Long-term survival in an infant with urethral atresia. J Urol. 1990;143(2):336-337. X-5. [pmid: 2299725].
238 Strauss RP, Davis JU. Prenatal detection and fetal surgery of clefts and craniofacial abnormalities in humans: social and ethical issues. Cleft Palate J. 1990;27(2):176-182. discussion 182–183. X-1. [pmid: 2340638].
239 Wood MK. Repair of ductus diverticulum aneurysm. Ann Thorac Surg. 1990;49(1):169. X-5, X-6. [pmid: 2297270].
240 Bosman G, et al. Prenatal diagnosis, management and outcome of fetal uretero-pelvic junction obstruction. Ultrasound Med Biol. 1991;17(2):117-120. X-6. [pmid: 2053207].
241 Brandt ML, et al. Surgical indications in antenatally diagnosed ovarian cysts. J Pediatr Surg. 1991;26(3):276-281. discussion 281–282. X-6. [pmid: 1827651].
242 Brown D, Andersen HF, Elkins TE. An analysis of the ACOG and AAP ethics statements on conflicts in maternal-fetal care. J Clin Ethics. 1991;2(1):19-22. discussion 23–24. X-1. [pmid: 1932792].
243 Cochrane D, et al. The effects of labor and delivery on spinal cord function and ambulation in patients with meningomyelocele. Childs Nerv Syst. 1991;7(6):312-315. X-6. [pmid: 1764706].
244 Dainiak N. In utero transplantation of hematopoietic stem cells. Blood Cells. 1991;17(2):376-378. X-3. [pmid: 1680505].
245 Dildy GA III, et al. Porencephalic cyst: a complication of fetal intravascular transfusion. Am J Obstet Gynecol. 1991;165(1):76-78. X-5. [pmid: 1853920].
246 Gau GS, Napier K, Bhundia J. Use of a tissue adhesive to repair fetal bodies after dissection. J Clin Pathol. 1991;44(9):759-760. X-6. [pmid: 1918405].
247 Harrison MR, Adzick NS. The fetus as a patient. Surgical considerations. Ann Surg. 1991;213(4):279-291. discussion 277–278. X-1. [pmid: 2009009].
248 King PA, et al. Recurrent congenital chylothorax. Prenat Diagn. 1991;11(10):809-811. X-6. [pmid: 1800993].
249 Knopoff KA. Can a pregnant woman morally refuse fetal surgery. Calif Law Rev. 1991;79(2):499-540. X-1. [pmid: 11659841].
250 Krummel TM, et al. Characteristics of fetal repair. Prog Clin Biol Res. 1991;365:167-176. X-1. [pmid: 1862129].
251 Lammers PK, Palmer PN. Surgeons discuss ambulatory surgery, legislative concerns, dangers of transfusions, surgical advances. AORN J. 1991;53(1):16-29. X-1. [pmid: 1671633].
252 Levine AH. Fetal surgery. In utero repair of congenital diaphragmatic hernia. AORN J. 1991;54(1):16-19. X-1. [pmid: 1883238].
253 Morykwas MJ, et al. Monodelphis domesticus: a model for early developmental wound healing. Ann Plast Surg. 1991;27(4):327-331. X-3. [pmid: 1772223].
254 Nakayama DK, et al. The newborn with hydrops and sacrococcygeal teratoma. J Pediatr Surg. 1991;26(12):1435-1438. X-6. [pmid: 1765933].
255 Neilson IR, et al. Congenital adenomatoid malformation of the lung: current management and prognosis. J Pediatr Surg. 1991;26(8):975-980. discussion 980–981. X-6. [pmid: 1919992].
256 Organ CH Jr, Henderson VJ. Surgery. JAMA. 1991;265(23):3172-3175. X-1. [pmid: 1828274].
257 Ronderos-Dumit D, et al. Uterine-peritoneal amniotic fluid leakage: an unusual complication of intrauterine shunting. Obstet Gynecol. 1991;78(5 Pt 2):913-915. X-5. [pmid: 1923226].
258 Sakala EP, Leon ZA, Rouse GA. Management of antenatally diagnosed fetal ovarian cysts. Obstet Gynecol Surv. 1991;46(7):407-414. X-6. [pmid: 1876353].
259 Sonek JD, Foley MR, Iams JD. Spontaneous regression of a large intrathoracic fetal lesion before birth. Am J Perinatol. 1991;8(1):41-43. X-5. [pmid: 1987967].
260 Touraine JL. Stem cell transplantation in primary immunodeficiency, with special reference to the first prenatal, in utero, transplants. Allergol Immunopathol (Madr). 1991;19(2):49-51. X-6. [pmid: 1685306].
261 Touraine JL, et al. In utero transplantation of hemopoietic stem cells in humans. Transplant Proc. 1991;23(1 Pt 2):1706-1708. X-6. [pmid: 1671181].
262 Weiner CP, et al. Management of fetal hemolytic disease by cordocentesis. II. Outcome of treatment. Am J Obstet Gynecol. 1991;165(5 Pt 1):1302-1307. X-6. [pmid: 1957851].
263 Weintraub WH. What’s new in surgery for 1991? Pediatric surgery. Bull Am Coll Surg. 1991;76(1):40-42. 79. X-1. [pmid: 10170671].
264 Weston MJ, Andrews H. Case report: in-utero aspiration of sacrococcygeal cyst. Clin Radiol. 1991;44(2):119-120. X-5, X-6. [pmid: 1884579].
265 Yilmaz AT, et al. Ligation in adult persistent ductus arteriosus. J Cardiovasc Surg (Torino). 1991;32(5):575-580. X-6.
266 Abbott JF, et al. Prenatal diagnosis of vestigial tail. J Ultrasound Med. 1992;11(1):53-55. X-5, X-6. [pmid: 1740834].
267 Adzick NS, Longaker MT. Scarless fetal healing. Therapeutic implications. Ann Surg. 1992;215(1):3-7. X-1. [pmid: 1731647].
268 Andersen K, Kaad PH. Congenital sideroblastic anaemia with intrauterine symptoms and early lethal outcome. Acta Paediatr. 1992;81(8):652-653. X-5, X-6. [pmid: 1392398].
269 Balci S, et al. Meckel Gruber syndrome: a case diagnosed in utero. Turk J Pediatr. 1992;34(3):179-185. X-5, X-6. [pmid: 1485386].
270 Bayer I, Samuel N, Chaimoff C. Surgical emergency in the fetus as indication for cesarean section. Int J Gynaecol Obstet. 1992;39(4):333-334. X-6. [pmid: 1361468].
271 Boglino C, et al. Neurotensin localization in adenomatoid cystic malformation versus normal lung: preliminary report of six consecutive cases. J Pediatr Surg. 1992;27(1):57-60. X-6. [pmid: 1552446].
272 Budorick NE, et al. Spontaneous improvement of intrathoracic masses diagnosed in utero. J Ultrasound Med. 1992;11(12):653-662. X-6. [pmid: 1494197].
273 dell’Agnola CA, et al. Prenatal ultrasonography and early surgery for congenital cystic disease of the lung. J Pediatr Surg. 1992;27(11):1414-1417. X-6. [pmid: 1479501].
274 Ginsberg NA, et al. Term birth after midtrimester hysterotomy and selective delivery of an acardiac twin. Am J Obstet Gynecol. 1992;167(1):33-37. X-5. [pmid: 1442950].
275 Gladstone DJ, et al. Course of pregnancy and fetal outcome following maternal exposure to carbamazepine and phenytoin: a prospective study. Reprod Toxicol. 1992;6(3):257-261. X-6. [pmid: 1591483].
276 Hosoda Y, et al. Characteristics and management of patients with fetal neuroblastoma. J Pediatr Surg. 1992;27(5):623-625. X-5, X-6. [pmid: 1625135].
277 Jennings RW, et al. New techniques in fetal surgery. J Pediatr Surg. 1992;27(10):1329-1333. X-3. [pmid: 1403515].
278 Mandell J, et al. Aspiration of bilateral perinephric urinomas and vesicoamniotic shunt placement in fetal bladder outlet obstruction. J Ultrasound Med. 1992;11(12):679-682. X-5. [pmid: 1494202].
279 Muller-Leisse C, et al. Ovarian cysts in the fetus and neonate—changes in sonographic pattern in the follow-up and their management. Pediatr Radiol. 1992;22(6):395-400. X-6. [pmid: 1437358].
280 Murphy JJ, Blair GK, Fraser GC. Coagulopathy associated with large sacrococcygeal teratomas. J Pediatr Surg. 1992;27(10):1308-1310. X-6. [pmid: 1403511].
281 Otamiri G, et al. Neurological adaptation of infants delivered by emergency or elective cesarean section. Acta Paediatr. 1992;81(10):797-801. X-6. [pmid: 1421886].
282 Pearl JM, et al. Repair of conotruncal abnormalities with the use of the valved conduit: improved early and midterm results with the cryopreserved homograft. J Am Coll Cardiol. 1992;20(1):191-196. X-6. [pmid: 1607524].
283 Prasad K, Radhakrishnan S, Sinha N. Extensive calcification of pulmonary arteries with left-to-right shunting across the arterial duct. Int J Cardiol. 1992;35(3):419-421. X-5, X-6. [pmid: 1612808].
284 Rosseau GL, McCullough DC, Joseph AL. Current prognosis in fetal ventriculomegaly. J Neurosurg. 1992;77(4):551-555. X-6. [pmid: 1527613].
285 Schaupp W, et al. Reconstruction of the arteria carotis communis in newborn following extracorporeal membrane oxygenation (ECMO). Eur J Pediatr Surg. 1992;2(2):78-80. X-6. [pmid: 1610755].
286 Slavin S, et al. Clinical application of intrauterine bone marrow transplantation for treatment of genetic diseases--feasibility studies. Bone Marrow Transplant. 1992;9(Suppl 1):189-190. X-6. [pmid: 1504665].
287 Tanaka M, et al. Intravascular pancuronium bromide infusion for prenatal diagnosis of twin-twin transfusion syndrome. Fetal Diagn Ther. 1992;7(1):36-40. X-5. [pmid: 1610501].
288 Thomas RL. Prenatal diagnosis of giant cystic hygroma: prognosis, counselling, and management; case presentation and review of the recent literature. Prenat Diagn. 1992;12(11):919-923. X-5, X-6. [pmid: 1494545].
289 Touraine JL. Rationale and results of in utero transplants of stem cells in humans. Bone Marrow Transplant. 1992;10(Suppl 1):121-126. X-6. [pmid: 1355682].
290 Zaninovic AC, et al. Congenital bladder rupture and urine ascites secondary to a sacrococcygeal teratoma. Pediatr Radiol. 1992;22(7):509-511. X-5. [pmid: 1491908].
291 Belik J, et al. Fetal ductus arteriosus ligation. Pulmonary vascular smooth muscle biochemical and mechanical changes. Circ Res. 1993;72(3):588-596. X-3. [pmid: 8431986].
292 Benya EC, et al. Cystic sonographic appearance of extralobar pulmonary sequestration. Pediatr Radiol. 1993;23(8):605-607. X-5, X-6. [pmid: 8152876].
293 Brus F, et al. Non-immune hydrops fetalis and bilateral pulmonary hypoplasia in a newborn infant with extralobar pulmonary sequestration. Acta Paediatr. 1993;82(4):416-418. X-5, X-6. [pmid: 8318813].
294 Cowles T, Furman P, Wilkins I. Prenatal diagnosis of Dandy-Walker malformation in a family displaying X-linked inheritance. Prenat Diagn. 1993;13(2):87-91. X-5, X-6. [pmid: 8464840].
295 Delius R, et al. Venovenous compares favorably with venoarterial access for extracorporeal membrane oxygenation in neonatal respiratory failure. J Thorac Cardiovasc Surg. 1993;106(2):329-338. X-6. [pmid: 8341073].
296 Dumez Y, et al. Prenatal management of congenital cystic adenomatoid malformation of the lung. J Pediatr Surg. 1993;28(1):36-41. X-6. [pmid: 8429468].
297 Flake AW. Fetal sacrococcygeal teratoma. Semin Pediatr Surg. 1993;2(2):113-120. X-6. [pmid: 8062028].
298 Gonen R, et al. The effect of drainage of fetal chylothorax on cardiac and blood vessel hemodynamics. J Clin Ultrasound. 1993;21(4):265-268. X-5. [pmid: 8478459].
299 Hawkins E, et al. Occult malignancy in neonatal sacrococcygeal teratomas. A report from a Combined Pediatric Oncology Group and Children’s Cancer Group study. Am J Pediatr Hematol Oncol. 1993;15(4):406-409. X-6. [pmid: 7692755].
300 Heffez DS, et al. Intrauterine repair of experimental surgically created dysraphism. Neurosurgery. 1993;32(6):1005-1010. X-3, X-6. [pmid: 8327074].
301 Howell LJ, Adzick NS, Harrison MR. The Fetal Treatment Center. Semin Pediatr Surg. 1993;2(2):143-146. X-1. [pmid: 8062032].
302 Jelsema RD, et al. Prenatal diagnosis of congenital diaphragmatic hernia not amenable to prenatal or neonatal repair: Brachmann-de Lange syndrome. Am J Med Genet. 1993;47(7):1022-1023. X-5. [pmid: 8291516].
303 Kum CK, Wong YC, Prabhakaran K. Management of fetal sacroccocygeal teratoma. Ann Acad Med Singapore. 1993;22(3):377-380. X-6. [pmid: 8373123].
304 MacMahon RA, et al. In utero repair of diaphragmatic hernia. J Paediatr Child Health. 1993;9(5):393-395. X-6. [pmid: 8240871].
305 Majid AA. Closure of the patent ductus arteriosus with a Ligaclip through a minithoracotomy. Chest. 1993;103(5):1512-1514. X-6. [pmid: 8486035].
306 Malnofski MJ, et al. Prenatal ultrasonic diagnosis of retroperitoneal cystic lymphangioma. J Ultrasound Med. 1993;12(7):427-429. X-6. [pmid: 8355339].
307 Mashiach R, et al. Antenatal ultrasound diagnosis of congenital cystic adenomatoid malformation of the lung: spontaneous resolution in utero. J Clin Ultrasound. 1993;21(7):453-457. X-5, X-6. [pmid: 8370805].
308 Meagher SE, et al. Disappearing lung echogenicity in fetal bronchopulmonary malformations: a reassuring sign. Prenat Diagn. 1993;13(6):495-501. X-6. [pmid: 8372075].
309 Nyberg DA, et al. Prenatal sonographic findings of trisomy 18: review of 47 cases. J Ultrasound Med. 1993;12(2):103-113. X-6. [pmid: 8468736].
310 Obwegeser R, Deutinger J, Bernaschek G. Fetal pulmonary cyst treated by repeated thoracocentesis. Am J Obstet Gynecol. 1993;169(6):1622-1624. X-5. [pmid: 8267077].
311 Ruiz CE, et al. Brief report: stenting of the ductus arteriosus as a bridge to cardiac transplantation in infants with the hypoplastic left-heart syndrome. N Engl J Med. 1993;328(22):1605-1608. X-6. [pmid: 8487802].
312 Shalev E, Peleg D. Fetal cardiac resuscitation. Lancet. 1993;341(8840):305-306. X-5, X-6. [pmid: 8093938].
313 Taguchi M, et al. Prenatal diagnosis of congenital cystic adenomatoid malformation of the lung. Fetal Diagn Ther. 1993;8(2):114-118. X-5, X-6. [pmid: 8338623].
314 Tariq TA, Korejo R. Evaluation of the role of craniotomy in developing countries. J Pak Med Assoc. 1993;43(2):30-32. X-6. [pmid: 8497100].
315 Touraine JL. In utero fetal liver cell transplantation in the treatment of immunodeficient or thalassemic human fetuses. Transfus Sci. 1993;14(3):299-304. X-6. [pmid: 10146342].
316 Turco AE, et al. Prenatal testing in a fetus at risk for autosomal dominant polycystic kidney disease and autosomal recessive junctional epidermolysis bullosa with pyloric atresia. Am J Med Genet. 1993;47(8):1225-1230. X-5, X-6. [pmid: 8291561].
317 Verloes A, et al. Brachymorphism-onychodysplasia-dysphalangism syndrome. J Med Genet. 1993;30(2):158-161. X-5, X-6. [pmid: 8445623].
318 Walton JM, et al. Fetal tumors associated with hydrops: the role of the pediatric surgeon. J Pediatr Surg. 1993;28(9):1151-1153. X-6. [pmid: 8308682].
319 Westaby S, et al. Replacement of the thoracic aorta with collagen-impregnated woven Dacron grafts. Early results. J Thorac Cardiovasc Surg. 1993;106(3):427-433. X-6. [pmid: 8361183].
320 Wilson JM, DiFiore JW, Peters CA. Experimental fetal tracheal ligation prevents the pulmonary hypoplasia associated with fetal nephrectomy: possible application for congenital diaphragmatic hernia. J Pediatr Surg. 1993;28(11):1433-1439. discussion 1439–1440. X-3, X-6. [pmid: 8301455].
321 Blachar A, et al. Evaluation of prenatally diagnosed hydronephrosis by morphometric measurements of the kidney. Pediatr Radiol. 1994;24(2):131-134. X-6. [pmid: 8078715].
322 Crombleholme TM, Murray TA, Harris BH. Diagnosis and management of fetal neuroblastoma. Curr Opin Obstet Gynecol. 1994;6(2):199-202. X-5, X-6. [pmid: 8193262].
323 DiFiore JW, et al. Experimental fetal tracheal ligation reverses the structural and physiological effects of pulmonary hypoplasia in congenital diaphragmatic hernia. J Pediatr Surg. 1994;29(2):248-256. discussion 256–257. X-3, X-6. [pmid: 8176601].
324 Dumez Y, et al. Meckel-Gruber syndrome: prenatal diagnosis at 10 menstrual weeks using embryoscopy. Prenat Diagn. 1994;14(2):141-144. X-5. [pmid: 8183850].
325 Elami A, Laks H, Pearl JM. Truncal valve repair: initial experience with infants and children. Ann Thorac Surg. 1994;57(2):397-401. discussion 402. X-6. [pmid: 8311603].
326 Geirsson RT, Palsson G. Prenatal thoracocentesis may be lifesaving in congenital chylothorax. J Perinat Med. 1994;22(5):447-448. X-5, X-6. [pmid: 7791021].
327 Hecher K, Sullivan ID, Nicolaides KH. Temporary iatrogenic fetal tricuspid valve atresia in a case of twin to twin transfusion syndrome. Br Heart J. 1994;72(5):457-460. X-5. [pmid: 7818963].
328 Hedrick MH, et al. Plug the lung until it grows (PLUG): a new method to treat congenital diaphragmatic hernia in utero. J Pediatr Surg. 1994;29(5):612-617. X-3. [pmid: 8035268].
329 Hershkovitz E, et al. Prenatal ultrasonic diagnosis of nonhypertrophic pyloric stenosis associated with intestinal malrotation. J Clin Ultrasound. 1994;22(1):52-54. X-6. [pmid: 8294579].
330 Hill AE, Beattie F. Does caesarean section delivery improve neurological outcome in open spina bifida. Eur J Pediatr Surg. 1994;4(Suppl 1):32-34. X-6. [pmid: 7766550].
331 Holzgreve W, et al. A simpler technique for umbilical-cord blockade of an acardiac twin. N Engl J Med. 1994;331(1):56-57. X-5. [pmid: 8202113].
332 Inoue M, et al. Antenatal diagnosis of sacrococcygeal teratoma with hydrops fetalis; a case report. Eur J Pediatr Surg. 1994;4(2):125-127. X-5, X-6. [pmid: 8025097].
333 Kaw YT. Congenital cystic adenomatoid malformation of the lung. Report of a case with cytologic findings. Acta Cytol. 1994;38(2):275-278. X-5, X-6. [pmid: 8147225].
334 Liu HY, et al. Clinical outcome and management of prenatally diagnosed primary megaureters. J Urol. 1994;152(2 Pt 2):614-617. X-6. [pmid: 8021982].
335 MacGillivray TE, et al. Vascular changes with in utero correction of diaphragmatic hernia. J Pediatr Surg. 1994;29(8):992-996. X-6. [pmid: 7965536].
336 McCullagh M, et al. Accuracy of prenatal diagnosis of congenital cystic adenomatoid malformation. Arch Dis Child. 1994;71(2):F111-F113. X-6. [pmid: 7979463].
337 Porreco RP, et al. Palliative fetal surgery for diaphragmatic hernia. Am J Obstet Gynecol. 1994;170(3):833-884. X-5. [pmid: 7511334].
338 Quintero RA, et al. Brief report: umbilical-cord ligation of an acardiac twin by fetoscopy at 19 weeks of gestation. N Engl J Med. 1994;330(7):469-471. X-5. [pmid: 8289853].
339 Rodeck CH, Roberts LJ. Successful treatment of fetal cardiac arrest by left ventricular exchange transfusion. Fetal Diagn Ther. 1994;9(4):213-217. X-5, X-6. [pmid: 7945899].
340 Sakala EP, et al. Spontaneous, in utero regression of antenatally diagnosed solid fetal chest masses. A report of two cases. J Reprod Med. 1994;39(7):531-536. X-6. [pmid: 7966044].
341 Sakala EP, Perrott WS, Grube GL. Sonographic characteristics of antenatally diagnosed extralobar pulmonary sequestration and congenital cystic adenomatoid malformation. Obstet Gynecol Surv. 1994;49(9):647-655. X-1. [pmid: 7991233].
342 Sharara FI, Khoury AN. Prenatal diagnosis of a giant cavernous hemangioma in association with nonimmune hydrops. A case report. J Reprod Med. 1994;39(7):547-549. X-5. [pmid: 7966048].
343 Skupski DW, et al. Rapid exclusion of chromosomal aneuploidies by fluorescence in situ hybridization prior to fetal surgery for obstructive uropathy—a case report. Fetal Diagn Ther. 1994;9(5):353-356. X-5. [pmid: 7818786].
344 Thorpe-Beeston JG, Nicolaides KH. Cystic adenomatoid malformation of the lung: prenatal diagnosis and outcome. Prenat Diagn. 1994;14(8):677-688. X-6. [pmid: 7991510].
345 Weiner CP, Ludomirski A. Diagnosis, pathophysiology, and treatment of chronic twin-to-twin transfusion syndrome. Fetal Diagn Ther. 1994;9(5):283-290. X-6. [pmid: 7818775].
346 Westgren M, Ringden O. Fetal to fetal transplantation. Acta Obstet Gynecol Scand. 1994;73(5):371-372. X-1, X-6. [pmid: 7912028].
347 Wilson RD, et al. In utero decompression of umbilical cord angiomyxoma followed by vaginal delivery. Am J Obstet Gynecol. 1994;171(5):1383-1385. X-5. [pmid: 7977553].
348 Achiron R, et al. Fetal lung hyperechogenicity: prenatal ultrasonographic diagnosis, natural history and neonatal outcome. Ultrasound Obstet Gynecol. 1995;6(1):40-42. X-6. [pmid: 8528800].
349 Aguirre OA, et al. Resolution of unilateral fetal hydrothorax with associated non-immune hydrops after intrauterine thoracentesis. Ultrasound Obstet Gynecol. 1995;5(5):346-348. X-5. [pmid: 7614142].
350 Allan LD, et al. Survival after fetal aortic balloon valvoplasty. Ultrasound Obstet Gynecol. 1995;5(2):90-91. X-5. [pmid: 7719873].
351 Barret J, et al. The prognostic factors in the prenatal diagnosis of the echogenic fetal lung. Prenat Diagn. 1995;15(9):849-853. X-1. [pmid: 8559756].
352 Bromley B, et al. Fetal lung masses: prenatal course and outcome. J Ultrasound Med. 1995;14(12):927-936. quiz 1378. X-6. [pmid: 8583529].
353 Brown MF, et al. Successful prenatal management of hydrops, caused by congenital cystic adenomatoid malformation, using serial aspirations. J Pediatr Surg. 1995;30(7):1098-1099. X-5. [pmid: 7472941].
354 Chisholm JC, et al. Persistent hemolysis after transcatheter occlusion of a patent ductus arteriosus: surgical ligation of the duct over the occlusion device. Pediatr Cardiol. 1995;16(4):194-196. X-6. [pmid: 7567667].
355 Crombleholme TM, et al. Amniotic band syndrome in fetal lambs. I: Fetoscopic release and morphometric outcome. J Pediatr Surg. 1995;30(7):974-978. X-3. [pmid: 7472956].
356 De DH, Pezzella AT. Aneurysm following ligation of patent ductus arteriosus. Tex Heart Inst J. 1995;22(4):324-326. X-6. [pmid: 8605434].
357 Elchalal U, et al. Prenatal diagnosis of acute bladder distension associated with fetal sacrococcygeal teratoma—a case report. Prenat Diagn. 1995;15(12):1160-1164. X-5. [pmid: 8750297].
358 Foley MR, et al. Use of the Foley Cordostat grasping device for selective ligation of the umbilical cord of an acardiac twin: a case report. Am J Obstet Gynecol. 1995;172(1 Pt 1):212-214. X-5. [pmid: 7847539].
359 Hashim E, et al. Reversible tracheal obstruction in the fetal sheep: effects on tracheal fluid pressure and lung growth. J Pediatr Surg. 1995;30(8):1172-1177. X-3. [pmid: 7472976].
360 Hecher K, Ville Y, Nicolaides KH. Color Doppler ultrasonography in the identification of communicating vessels in twin-twin transfusion syndrome and acardiac twins. J Ultrasound Med. 1995;14(1):37-40. X-6. [pmid: 7707475].
361 Hsu KF, et al. Complete intrauterine resolution of fetal congenital cystic adenomatoid malformation of the lung type III. J Ultrasound Med. 1995;14(11):871-875. X-6. [pmid: 8551556].
362 King SJ, Pilling DW, Walkinshaw S. Fetal echogenic lung lesions: prenatal ultrasound diagnosis and outcome. Pediatr Radiol. 1995;25(3):208-210. X-6. [pmid: 7644306].
363 Luks FI. Fetal surgery. Baillieres Clin Obstet Gynaecol. 1995;9(3):571-577. X-1. [pmid: 8846557].
364 Meagher SE, et al. Successful outcome with serial amniocenteses for polyhydramnios complicating cystic adenomatoid malformation of the lung. Aust N Z J Obstet Gynaecol. 1995;35(3):326-328. X-5. [pmid: 8546657].
365 Meuli M, et al. Creation of myelomeningocele in utero: a model of functional damage from spinal cord exposure in fetal sheep. J Pediatr Surg. 1995;30(7):1028-1032. discussion 1032–1033. X-3. [pmid: 7472926].
366 Meuli-Simmen C, et al. Fetal reconstructive surgery: experimental use of the latissimus dorsi flap to correct myelomeningocele in utero. Plast Reconstr Surg. 1995;96(5):1007-1011. X-3. [pmid: 7568473].
367 Millicovsky G, Lazar ML. Spina bifida: role of neural tissue damage during pregnancy in producing spinal paralysis. Obstet Gynecol. 1995;86(2):300-301. X-1. [pmid: 7617367].
368 Morrow RJ, et al. Midtrimester thoracoamniotic shunting for the treatment of fetal hydrops. Fetal Diagn Ther. 1995;10(2):92-94. X-5. [pmid: 7794522].
369 Munoz H, et al. Prenatal sonographic findings of a large fetal cardiac fibroma. J Ultrasound Med. 1995;14(6):479-481. X-5. [pmid: 7658519].
370 Parilla BV, Chen GW. Fetal thoracentesis for cystic adenomatoid malformation of the lung. Am J Obstet Gynecol. 1995;172(2 Pt 1):717. X-5. [pmid: 7856713].
371 Quintero RA, et al. Percutaneous fetal cystoscopy and endoscopic fulguration of posterior urethral valves. Am J Obstet Gynecol. 1995;172(1 Pt 1):206-209. X-5. [pmid: 7847537].
372 Robertson FM, et al. Devascularization and staged resection of giant sacrococcygeal teratoma in the premature infant. J Pediatr Surg. 1995;30(2):309-311. X-5. [pmid: 7738756].
373 Shipley CF III, Simmons CL, Nelson GH. Intrauterine diagnosis of hydrothorax in a fetus who had a combination chylothorax and pulmonary sequestration after delivery. J Perinatol. 1995;15(3):237-239. X-5. [pmid: 7666275].
374 Taguchi T, et al. Antenatal diagnosis and surgical management of congenital cystic adenomatoid malformation of the lung. Fetal Diagn Ther. 1995;10(6):400-407. X-6. [pmid: 8579779].
375 Uchiyama M, et al. A huge immature cervical teratoma in a newborn: report of a case. Surg Today. 1995;25(8):737-740. X-6. [pmid: 8520169].
376 Watanabe M, et al. Left aortic arch with right descending aorta and right ligamentum arteriosum associated with d-TGA and large VSD: surgical treatment of a rare form of vascular ring. J Pediatr Surg. 1995;30(9):1363-1365. X-5. [pmid: 8523247].
377 Welch CR, et al. Needle modifications for invasive fetal procedures. Obstet Gynecol. 1995;85(1):113-117. X-6. [pmid: 7800306].
378 Willcourt RJ, et al. Laparoscopic ligation of the umbilical cord of an acardiac fetus. J Am Assoc Gynecol Laparosc. 1995;2(3):319-321. X-5. [pmid: 9050576].
379 Ahmad FK, et al. Isolated unilateral fetal pleural effusion: the role of sonographic surveillance and in utero therapy. Fetal Diagn Ther. 1996;11(6):383-389. X-5. [pmid: 9115624].
380 Blanch G, et al. Internalization of pleuroamniotic shunt causing neonatal demise. Fetal Diagn Ther. 1996;11(1):32-36. X-5. [pmid: 8719719].
381 Bloechle M, et al. Neuroectodermal cyst may be a rare differential diagnosis of fetal sacrococcygeal teratoma: first case report of a prenatally observed neuroectodermal cyst. Ultrasound Obstet Gynecol. 1996;7(1):64-67. X-5, X-6. [pmid: 8932637].
382 Chen CP, et al. Ultrasound-guided fluid aspiration and prenatal diagnosis of duplicated hydrometrocolpos with uterus didelphys and septate vagina. Prenat Diagn. 1996;16(6):572-576. X-5. [pmid: 8809902].
383 Crombleholme TM, et al. Prenatal diagnosis and the pediatric surgeon: the impact of prenatal consultation on perinatal management. J Pediatr Surg. 1996;31(1):156-162. discussion 162–163. X-6. [pmid: 8632271].
384 Crombleholme TM, et al. Fetoscopic cord ligation to prevent neurological injury in monozygous twins. Lancet. 1996;348(9021):191. X-5. [pmid: 8684164].
385 dell’Agnola C, et al. Advantages of prenatal diagnosis and early surgery for congenital cystic disease of the lung. J Perinat Med. 1996;24(6):621-631. X-6. [pmid: 9120745].
386 DiFederico EM, Harrison M, Matthay MA. Pulmonary edema in a woman following fetal surgery. Chest. 1996;109(4):1114-1117. X-5. [pmid: 8635343].
387 Flake AW. Fetal surgery for congenital diaphragmatic hernia. Semin Pediatr Surg. 1996;5(4):266-274. , X-5. [pmid: 8936656].
388 Gundogdu HZ, Senocak ME. Intrauterine intussusception due to Meckel’s diverticulum as a cause of ileal atresia: analysis of 2 cases. Eur J Pediatr Surg. 1996;6(1):52-54. X-6. [pmid: 8721182].
389 Habal MB. Perspectives on what’s new in plastic surgery. The new millennium. Clin Plast Surg. 1996;23(1):1-2. X-1. [pmid: 8617020].
390 Haddad B, et al. The congenital mesoblastic nephroma: a case report of prenatal diagnosis. Fetal Diagn Ther. 1996;11(1):61-66. X-5. [pmid: 8719724].
391 Hecher K, Hackeloer BJ. Intrauterine endoscopic laser surgery for fetal sacrococcygeal teratoma. Lancet. 1996;347(8999):470. X-5. [pmid: 8618503].
392 Hutchins GM, et al. Acquired spinal cord injury in human fetuses with myelomeningocele. Pediatr Pathol Lab Med. 1996;16(5):701-712. X-6. [pmid: 9025869].
393 Johnson JA, et al. Prenatal diagnosis of a fetal ventricular diverticulum associated with pericardial effusion: successful outcome following pericardiocentesis. Prenat Diagn. 1996;16(10):954-957. X-5. [pmid: 8938069].
394 Katz VL, et al. Fetal ovarian torsion appearing as a solid abdominal mass. J Perinatol. 1996;16(4):302-304. X-5, X-6. [pmid: 8866303].
395 Kaufman GE, D’Alton ME, Crombleholme TM. Decompression of fetal axillary lymphangioma to prevent dystocia. Fetal Diagn Ther. 1996;11(3):218-220. X-5. [pmid: 8739590].
396 Kubota M, et al. Clinical characteristics and natural history of antenatally diagnosed fetal uropathy. An analysis of 55 cases. Fetal Diagn Ther. 1996;11(4):275-285. X-6. [pmid: 8823609].
397 Kuller JA, et al. Cesarean delivery for fetal malformations. Obstet Gynecol Surv. 1996;51(6):371-375. X-1, X-6. [pmid: 8771576].
398 Lin RY, Adzick NS. The role of the fetal fibroblast and transforming growth factor-beta in a model of human fetal wound repair. Semin Pediatr Surg. 1996;5(3):165-174. X-6. [pmid: 8858763].
399 Mas M, Fontes J, Salcedo J. Ultrasonographic diagnosis of a twisted fetal ovarian cyst in utero. Int J Gynaecol Obstet. 1996;52(2):185-186. X-5, X-6. [pmid: 8855103].
400 Metkus AP, et al. Sonographic predictors of survival in fetal diaphragmatic hernia. J Pediatr Surg. 1996;31(1):148-111. discussion 151–152. X-6. [pmid: 8632269].
401 Mikulandra F, Perisa M, Stojnic E. When is fetal macrosomia (> or = 4500 g) an indication for caesarean section. Zentralbl Gynakol. 1996;118(8):441-447. X-6. [pmid: 8794545].
402 Miller JA, Corteville JE, Langer JC. Congenital cystic adenomatoid malformation in the fetus: natural history and predictors of outcome. J Pediatr Surg. 1996;31(6):805-808. X-6. [pmid: 8783108].
403 Noia G, et al. Double shunt in a case of fetal low-level obstructive uropathy. Fetal Diagn Ther. 1996;11(5):313-317. X-5. [pmid: 8894625].
404 Petrikovsky B, et al. Single-needle insertion technique for thoracocentesis for bilateral pleural effusions. Fetal Diagn Ther. 1996;11(1):26-31. X-5. [pmid: 8719718].
405 Skarsgard ED, et al. Fetal endoscopic tracheal occlusion (‘Fetendo-PLUG’) for congenital diaphragmatic hernia. J Pediatr Surg. 1996;31(10):1335-1338. X-3. [pmid: 8906656].
406 Smulian JC, et al. Color and duplex Doppler sonographic investigation of in utero spontaneous regression of pulmonary sequestration. J Ultrasound Med. 1996;15(11):789-792. X-6. [pmid: 8908591].
407 Tomlinson MW, et al. Correction of hemodynamic abnormalities by vesicoamniotic shunting in familial congenital megacystis. Fetal Diagn Ther. 1996;11(1):46-49. X-5. [pmid: 8719721].
408 VanderWall KJ, et al. Fetal endoscopic (‘Fetendo’) tracheal clip. J Pediatr Surg. 1996;31(8):1101-1103. discussion 1103–1104. X-3. [pmid: 8863243].
409 Adzick NS, et al. A rapidly growing fetal teratoma. Lancet. 1997;349(9051):538. X-5. [pmid: 9048793].
410 Bakos O. Intrauterine cephalocentesis: a case report. Fetal Diagn Ther. 1997;12(5):296-297. X-5. [pmid: 9430212].
411 Barrett JF, et al. Fetal urine production rates following intrauterine transfusion. Fetal Diagn Ther. 1997;12(6):343-347. X-6. [pmid: 9475364].
412 Bromley B, Benacerraf BR. Unilateral lung hypoplasia: report of three cases. J Ultrasound Med. 1997;16(9):599-601. X-6. [pmid: 9321779].
413 Bruch SW, et al. Prenatal therapy for pericardial teratomas. J Pediatr Surg. 1997;32(7):1113-1115. X-6. [pmid: 9247245].
414 Cacciari A, et al. A series of 17 cases of congenital cystic adenomatoid malformation of the lung: management and outcome. Eur J Pediatr Surg. 1997;7(2):84-89. X-6. [pmid: 9165253].
415 Cass DL, et al. Cystic lung lesions with systemic arterial blood supply: a hybrid of congenital cystic adenomatoid malformation and bronchopulmonary sequestration. J Pediatr Surg. 1997;32(7):986-990. X-5. [pmid: 9247218].
416 Conte S, et al. One-stage repair of truncus arteriosus, CAVC, and TAPVC. Ann Thorac Surg. 1997;63(6):1781-1783. X-5. [pmid: 9205190].
417 Conte S, et al. Double-homograft repair of truncus arteriosus with severe truncal valve dysfunction. Scand Cardiovasc J. 1997;31(4):245-247. X-5. [pmid: 9291547].
418 Coplen DE. Prenatal intervention for hydronephrosis. J Urol. 1997;157(6):2270-2277. X-1. [pmid: 9146651].
419 d’Udekem Y, Rubay JE, Sluysmans T. A case of neonatal ductus arteriosus aneurysm. Cardiovasc Surg. 1997;5(3):338-339. X-5. [pmid: 9293372].
420 Fung TY, et al. Abdomino-amniotic shunting in isolated fetal ascites with polyhydramnios. Acta Obstet Gynecol Scand. 1997;76(7):706-707. X-5. [pmid: 9292649].
421 Gaiser RR, Cheek TG, Kurth CD. Anesthetic management of cesarean delivery complicated by ex utero intrapartum treatment of the fetus. Anesth Analg. 1997;84(5):1150-1153. X-6. [pmid: 9141951].
422 Graf JL, et al. Fetal hydrops after in utero tracheal occlusion. J Pediatr Surg. 1997;32(2):214-215. discussion 216. X-5. [pmid: 9044124].
423 Hecher K, Hackeloer BJ, Ville Y. Umbilical cord coagulation by operative microendoscopy at 16 weeks’ gestation in an acardiac twin. Ultrasound Obstet Gynecol. 1997;10(2):130-132. X-5. [pmid: 9286023].
424 Ito M, et al. Aspiration of giant hepatic cyst in the fetus in utero. Fetal Diagn Ther. 1997;12(4):221-225. X-5. [pmid: 9354881].
425 Kimber CP, et al. Antenatal intestinal vascular accident with subsequent small bowel atresia: case report. Ultrasound Obstet Gynecol. 1997;10(3):212-214. X-6. [pmid: 9339530].
426 Kohl T, et al. Fetoscopic and open transumbilical fetal cardiac catheterization in sheep. Potential approaches for human fetal cardiac intervention. Circulation. 1997;95(4):1048-1053. X-3. [pmid: 9054769].
427 Liberati M, et al. Cardiotocographic and Doppler velocimetric patterns, pre- and post-thoracentesis, in a case of fetal hydrothorax. Clin Exp Obstet Gynecol. 1997;24(2):109-111. X-5. [pmid: 9342479].
428 Lipshutz GS, et al. Prospective analysis of lung-to-head ratio predicts survival for patients with prenatally diagnosed congenital diaphragmatic hernia. J Pediatr Surg. 1997;32(11):1634-1636. X-6. [pmid: 9396544].
429 Meuli M, et al. The spinal cord lesion in human fetuses with myelomeningocele: implications for fetal surgery. J Pediatr Surg. 1997;32(3):448-452. X-6. [pmid: 9094015].
430 Morris C. Technology and the legal discourse of fetal autonomy. UCLA Womens Law J. 1997;8(1):47-97. X-1. [pmid: 16273687].
431 Mychaliska GB, et al. Operating on placental support: the ex utero intrapartum treatment procedure. J Pediatr Surg. 1997;32(2):227-230. discussion 230–231. X-6. [pmid: 9044127].
432 O’Toole SJ, et al. Tracheal ligation: the dark side of in utero congenital diaphragmatic hernia treatment. J Pediatr Surg. 1997;32(3):407-410. X-3. [pmid: 9094004].
433 Ozmen MN, et al. Prenatal diagnosis of gastric duplication cyst. J Ultrasound Med. 1997;16(3):219-222. X-6. [pmid: 9166822].
434 Rani R, Cameron A, Munro F. Prenatal diagnosis and management of urethral obstruction. J Obstet Gynaecol Res. 1997;23(1):59-62. X-6. [pmid: 9094819].
435 Samuel M, Burge DM, Griffiths DM. Prenatal diagnosis of laryngotracheoesophageal clefts. Fetal Diagn Ther. 1997;12(5):260-265. X-6. [pmid: 9430204].
436 Sanal M, et al. Fetus in fetu and cystic rectal duplication in a newborn. Eur J Pediatr Surg. 1997;7(2):120-121. X-5. [pmid: 9165263].
437 Sener T, et al. Ultrasonographic detection of single umbilical artery: a simple marker of fetal anomaly. Int J Gynaecol Obstet. 1997;58(2):217-221. X-6. [pmid: 9252258].
438 Shih HH, et al. Mature teratoma arising from an intra-abdominal undescended testis presenting as a fetal abdominal mass. Ultrasound Obstet Gynecol. 1997;10(3):209-211. X-5. [pmid: 9339529].
439 Sklansky M, et al. Intrapericardial teratoma in a twin fetus: diagnosis and management. Obstet Gynecol. 1997;89(5 Pt 2):807-809. X-5. [pmid: 9166328].
440 Tabsh KM, Theroux NL. Obstructive fetal hydronephrosis managed by amnioinfusions and bladder aspirations. Obstet Gynecol. 1997;90(4 Pt 2):679-680. X-5. [pmid: 11770594].
441 VanderWall KJ, et al. Fetendo-clip: a fetal endoscopic tracheal clip procedure in a human fetus. J Pediatr Surg. 1997;32(7):970-972. X-5. [pmid: 9247214].
442 Winderl LM, Silverman RK. Prenatal identification of a completely cystic internal sacrococcygeal teratoma (type IV). Ultrasound Obstet Gynecol. 1997;9(6):425-428. X-5. [pmid: 9239831].
443 Winters WD, et al. Congenital masses of the lung: changes in cross-sectional area during gestation. J Clin Ultrasound. 1997;25(7):372-377. X-6. [pmid: 9282802].
444 Wittman BK, et al. Complications of long-term drainage of fetal pleural effusion: case report and review of the literature. Am J Perinatol. 1997;14(8):443-447. X-6. [pmid: 9376003].
445 Adzick NS, et al. Successful fetal surgery for spina bifida. Lancet. 1998;352(9141):1675-1676. X-5. [pmid: 9853442].
446 Arabin B, et al. Treatment of twin-twin transfusion syndrome by laser and digoxin. Biophysical and angiographic evaluation. Fetal Diagn Ther. 1998;13(3):141-146. X-5. [pmid: 9708434].
447 Arias F, et al. Treatment of acardiac twinning. Obstet Gynecol. 1998;91(5 Pt 2):818-821. X-5. [pmid: 9572174].
448 Armentano G, et al. Fetal ovarian cysts: prenatal diagnosis and management. Report of two cases and review of literature. Clin Exp Obstet Gynecol. 1998;25(3):88-91. X-6. [pmid: 9856306].
449 Asano M, et al. Modified subclavian flap aortoplasty for coarctation repair in patients less than three months of age. Ann Thorac Surg. 1998;66(2):588-589. X-6. [pmid: 9725421].
450 Bakos O, Ewald U, Lindgren PG. Fetal cardiocentesis in care of severe Kell immunisation. Fetal Diagn Ther. 1998;13(6):372-374. X-5. [pmid: 9933822].
451 Bannister CM, Russell SA, Rimmer S. Pre-natal brain development of fetuses with a myelomeningocele. Eur J Pediatr Surg. 1998;8(Suppl 1):15-17. X-6. [pmid: 9926317].
452 Borghi F, et al. Embryologic bases of extended radical resection in pancreatic cancer. Arch Surg. 1998;133(3):297-301. X-6. [pmid: 9517744].
453 Bryant DR, et al. Limited usefulness of fetal weight in predicting neonatal brachial plexus injury. Am J Obstet Gynecol. 1998;179(3 Pt 1):686-689. X-6. [pmid: 9757972].
454 Chen CP, et al. Perinatal findings in a male fetus with congenital megacystis and anorectal malformations. Fetal Diagn Ther. 1998;13(6):348-351. X-5. [pmid: 9933817].
455 Chisholm CA, et al. Prenatal diagnosis and perinatal management of fetal sacrococcygeal teratoma. Am J Perinatol. 1998;15(8):503-505. X-6. [pmid: 9788651].
456 Davis CF, Sabharwal AJ. Management of congenital diaphragmatic hernia. Arch Dis Child Fetal Neonatal Ed. 1998;79(1):F1-F3. X-1. [pmid: 9797617].
457 Deprest JA, et al. Experience with fetoscopic cord ligation. Eur J Obstet Gynecol Reprod Biol. 1998;81(2):157-164. X-6. [pmid: 9989860].
458 Eapen RS, Rowland DG, Franklin WH. Effect of prenatal diagnosis of critical left heart obstruction on perinatal morbidity and mortality. Am J Perinatol. 1998;15(4):237-242. X-6. [pmid: 9565221].
459 Garcia AM, Morgan WM III, Bruner JP. In utero decompression of a cystic grade IV sacrococcygeal teratoma. Fetal Diagn Ther. 1998;13(5):305-308. X-5. [pmid: 9813425].
460 Graf JL, et al. A surprising histological evolution of preterm sacrococcygeal teratoma. J Pediatr Surg. 1998;33(2):177-179. X-6. [pmid: 9498382].
461 Hamada Y, et al. Rapid enlargement of a choledochal cyst: antenatal diagnosis and delayed primary excision. Pediatr Surg Int. 1998;13(5–6):419-421. X-5, X-6. [pmid: 9639632].
462 Holterman AX, et al. The natural history of sacrococcygeal teratomas diagnosed through routine obstetric sonogram: a single institution experience. J Pediatr Surg. 1998;33(6):899-903. X-6. [pmid: 9660225].
463 Housley HT, Harrison MR. Fetal urinary tract abnormalities. Natural history, pathophysiology, and treatment. Urol Clin North Am. 1998;25(1):63-73. X-1. [pmid: 9529537].
464 Howarth GR, et al. Management of early onset severe twin-twin transfusion syndrome in the absence of fetoscopic equipment by exteriorisation, ligation and replacement of the umbilical cord of the sacrificed twin. S Afr Med J. 1998;88(3):286. X-5. [pmid: 9608304].
465 Hubbard AM, Crombleholme TM. Anomalies and malformations affecting the fetal/neonatal chest. Semin Roentgenol. 1998;33(2):117-125. X-1. [pmid: 9583107].
466 Jamjoom AB, et al. Factors affecting the outcome of foetal hydrocephaly. Acta Neurochir (Wien). 1998;140(11):1121-1125. X-6. [pmid: 9870056].
467 Jikuya T, et al. Aortic dissection extending from ductus diverticulum aneurysm. Jpn J Thorac Cardiovasc Surg. 1998;46(7):595-598. X-5. [pmid: 9750440].
468 Kuga T, et al. Prune belly syndrome with penile and urethral agenesis: report of a case. J Pediatr Surg. 1998;33(12):1825-1828. X-5. [pmid: 9869063].
469 Lewis KM, et al. Complications of intrauterine placement of a vesicoamniotic shunt. Obstet Gynecol. 1998;91(5 Pt 2):825-827. X-5. [pmid: 9572177].
470 Martinez Ferro M, et al. Intrathoracic alimentary tract duplication cysts treated in utero by thoracoamniotic shunting. Fetal Diagn Ther. 1998;13(6):343-347. X-6. [pmid: 9933816].
471 Pschera H. Current status in intrauterine fetal stem cell therapy. J Obstet Gynaecol Res. 1998;24(6):419-424. X-1. [pmid: 10063237].
472 Reyes C, et al. Delayed repair of congenital diaphragmatic hernia with early high-frequency oscillatory ventilation during preoperative stabilization. J Pediatr Surg. 1998;33(7):1010-1014. discussion 1014–1016. X-6. [pmid: 9694086].
473 Riskin-Mashiah S, et al. In utero diagnosis of intrapericardial teratoma: a case for in utero open fetal surgery. Prenat Diagn. 1998;18(12):1328-1330. X-5. [pmid: 9885028].
474 Shapiro E, et al. Altered smooth muscle development and innervation in the lower genitourinary and gastrointestinal tract of the male human fetus with myelomeningocele. J Urol. 1998;160(3 Pt 2):1047-1053. discussion 1079. X-6. [pmid: 9719274].
475 Shimazaki Y, et al. Ruptured aneurysm of the ductus diverticulum into the pulmonary artery in a man: a successful repair. J Card Surg. 1998;13(2):146-149. X-5. [pmid: 10063964].
476 Sistino JJ. Foetal bypass: concepts and controversies. Perfusion. 1998;13(2):111-117. X-6. [pmid: 9533117].
477 Stelnicki EJ, et al. The in utero repair of Tessier number 7 lateral facial clefts created by amniotic band-like compression. J Craniofac Surg. 1998;9(6):557-562. discussion 563. X-3. [pmid: 10029770].
478 Stone CA, Quinn MW, Saxby PJ. Congenital skin loss following Nd:YAG placental photocoagulation. Burns. 1998;24(3):275-277. X-5. [pmid: 9677034].
479 Thakral CL, Maji DC, Sajwani MJ. Fetus-in-fetu: a case report and review of the literature. J Pediatr Surg. 1998;33(9):1432-1434. X-5, X-6. [pmid: 9766375].
480 van Gemert MJ, Major AL, Scherjon SA. Placental anatomy, fetal demise and therapeutic intervention in monochorionic twins and the transfusion syndrome: new hypotheses. Eur J Obstet Gynecol Reprod Biol. 1998;78(1):53-62. X-6. [pmid: 9605450].
481 Van Peborgh P, et al. Management of a case of twin-to-twin transfusion syndrome by a combined surgical approach. Fetal Diagn Ther. 1998;13(2):75-78. X-5. [pmid: 9650650].
482 Wilhelm C, et al. Ventriculomegaly diagnosed by prenatal ultrasound and mental development of the children. Fetal Diagn Ther. 1998;13(3):162-166. X-6. [pmid: 9708439].
483 Wilkinson C, et al. Is a rising caesarean section rate inevitable. Br J Obstet Gynaecol. 1998;105(1):45-52. X-6. [pmid: 9442161].
484 Ethical guidelines on human reproduction and women’s health. FIGO Committee for the Ethical Aspects of Human Reproduction and Women’s Health J Reprod Med. 1999;44(5):482-486. X-1.
485 Part III: pulmonary lesions—congenital cystic adenomatoid malformation (CCAM) or extralobar pulmonary sequestration (EPS). Tecnologica MAP Suppl. 1999:15-16. X-1.
486 Part II: congenital diaphragmatic hernia. Tecnologica MAP Suppl. 1999:14-15. X-1.
487 Part I: bilateral urinary tract obstruction. Tecnologica MAP Suppl. 1999:12-13. X-1.
488 Fetal surgery for prenatally diagnosed malformations. Tecnologica MAP Suppl. 1999:11-12. X-1.
489 al-Kouatly HB, Skupski DW. Intrauterine sling: a complication of the stuck twin syndrome. Ultrasound Obstet Gynecol. 1999;14(6):419-421. X-5. [pmid: 10658281].
490 Anandakumar C, et al. Direct intrauterine fetal therapy in a case of bronchopulmonary sequestration associated with non-immune hydrops fetalis. Ultrasound Obstet Gynecol. 1999;13(4):263-265. X-5. [pmid: 10341405].
491 Anteby EY, Sternhell K, Dicke JM. The fetus with gastroschisis managed by a trial of labor: antepartum and intrapartum complications. J Perinatol. 1999;19(7):521-524. X-6. [pmid: 10685303].
492 Bagolan P, et al. Cystic adenomatoid malformation of the lung: clinical evolution and management. Eur J Pediatr. 1999;158(11):879-882. X-6. [pmid: 10541940].
493 Baskin LS. Fetal genital anatomy reconstructive implications. J Urol. 1999;162(2):527-529. X-6. [pmid: 10411082].
494 Brookes JA, et al. Three-dimensional imaging of the postmortem fetus by MRI: early experience. Fetal Diagn Ther. 1999;14(3):166-171. X-6. [pmid: 10364668].
495 Chisholm CA, et al. Prenatal diagnosis and perinatal management of fetal sacrococcygeal teratoma. Am J Perinatol. 1999;16(1):47-50. X-6. [pmid: 10362082].
496 Chisholm CA, et al. Prenatal diagnosis and perinatal management of fetal sacrococcygeal teratoma. Am J Perinatol. 1999;16(2):89-92. X-6. [pmid: 10355916].
497 Chuileannain FN, Woodrow N, de Crespigny L. Prenatal diagnosis and management of sacrococcygeal teratoma. Aust N Z J Obstet Gynaecol. 1999;39(4):497-501. X-6. [pmid: 10687774].
498 Dommergues M, et al. The reasons for termination of pregnancy in the third trimester. Br J Obstet Gynaecol. 1999;106(4):297-303. X-6. [pmid: 10426234].
499 Evrard V, et al. Congenital parenchymatous malformations of the lung. World J Surg. 1999;23(11):1123-1132. X-6. [pmid: 10501874].
500 Flake AW, Crombleholme TM, Adzick NS. The current status and future potential of fetal intervention: image is everything. Comput Med Imaging Graph. 1999;23(1):51-57. X-1. [pmid: 10091869].
501 Gonen R, et al. Intrapartum drainage of fetal pleural effusion. Prenat Diagn. 1999;19(12):1124-1126. X-6. [pmid: 10590429].
502 Gotte K, et al. Congenital nasal hemangiopericytoma: intrauterine, intraoperative, and histologic findings. Ann Otol Rhinol Laryngol. 1999;108(6):589-593. X-6. [pmid: 10378528].
503 Hamada Y, et al. Prenatally diagnosed cystic neuroblastoma. Pediatr Surg Int. 1999;15(1):71-74. X-5, X-6. [pmid: 9914363].
504 Hirose H, et al. Spontaneously developed aneurysm of the ductus arteriosus in an adult. Ann Vasc Surg. 1999;13(2):229-231. X-5, X-6. [pmid: 10072468].
505 Hornung TS, et al. Neonatal ductus arteriosus aneurysm causing nerve palsies and airway compression: surgical treatment by decompression without excision. Pediatr Cardiol. 1999;20(2):158-160. X-5, X-6. [pmid: 9986898].
506 Howell LJ, Adzick NS. The essentials of a fetal therapy center. Semin Perinatol. 1999;23(6):535-540. X-1. [pmid: 10630549].
507 Howell LJ, Dunphy PM. Fetal surgery: exploring the challenges in nursing care. J Obstet Gynecol Neonatal Nurs. 1999;28(4):427-432. X-5.
508 Imamura M, et al. Improving early and intermediate results of truncus arteriosus repair: a new technique of truncal valve repair. Ann Thorac Surg. 1999;67(4):1142-1146. X-6. [pmid: 10320264].
509 Liechty KW, et al. Elevated platelet-derived growth factor-B in congenital cystic adenomatoid malformations requiring fetal resection. J Pediatr Surg. 1999;34(5):805-809. discussion 809–810. X-6. [pmid: 10359185].
510 Liechty KW, et al. The ex utero intrapartum treatment procedure for a large fetal neck mass in a twin gestation. Obstet Gynecol. 1999;93(5 Pt 2):824-825. X-5. [pmid: 10912408].
511 Liu SL, et al. 19-year follow-up of fetal myelomeningocele brought to term. Eur J Pediatr Surg. 1999;9(Suppl 1):12-14. X-6. [pmid: 10661783].
512 Lopoo JB, et al. Natural history of fetuses with cleft lip. Plast Reconstr Surg. 1999;103(1):34-38. X-6. [pmid: 9915161].
513 Lundvall L, Skibsted L, Graem N. Limb necrosis associated with twin-twin transfusion syndrome treated with YAG-laser coagulation. Acta Obstet Gynecol Scand. 1999;78(4):349-350. X-5. [pmid: 10203306].
514 Okamura M, et al. Fetal sacrococcygeal teratoma visualized by ultra-fast T2 weighted magnetic resonance imaging. Int J Gynaecol Obstet. 1999;65(2):191-193. X-6. [pmid: 10405065].
515 Porter HJ. Pulmonary hypoplasia. Arch Dis Child Fetal Neonatal Ed. 1999;81(2):F81-F83. X-1. [pmid: 10448173].
516 Ranzini AC, et al. Prenatal sonographic diagnosis of uterine rupture following open fetal surgery. Obstet Gynecol. 1999;93(5 Pt 2):826-827. X-5. [pmid: 10912409].
517 Schmidt M, et al. Magnetic resonance imaging of ductus arteriosus Botalli apertus in adulthood. Int J Cardiol. 1999;68(2):225-229. X-6. [pmid: 10189012].
518 Schreiber C, et al. Morphologic spectrum of Ebstein’s malformation: revisitation relative to surgical repair. J Thorac Cardiovasc Surg. 1999;117(1):148-155. X-6. [pmid: 9869769].
519 Schwarzler P, et al. Trisomy 10: first-trimester features on ultrasound, fetoscopy and postmortem of a case associated with increased nuchal translucency. Ultrasound Obstet Gynecol. 1999;13(1):67-70. X-5. [pmid: 10201090].
520 Sergi C, et al. Huge fetal sacrococcygeal teratoma with a completely formed eye and intratumoral DNA ploidy heterogeneity. Pediatr Dev Pathol. 1999;2(1):50-57. X-5, X-6. [pmid: 9841706].
521 Suzuki T, Fukuda T, Ito T. Modified end-to-end anastomosis combined with subclavian flap aortoplasty for repair of coarctation of the aorta with extended hypoplasia of the aortic isthmus. J Card Surg. 1999;14(5):359-362. X-6. [pmid: 10875590].
522 Takeuchi K, et al. Management of acute chylothorax with hydrops fetalis diagnosed in the third trimester of pregnancy. Fetal Diagn Ther. 1999;14(5):264-265. X-5. [pmid: 10529566].
523 Tame JD, et al. Level of postoperative analgesia is a critical factor in regulation of myometrial contractility after laparotomy in the pregnant baboon: implications for human fetal surgery. Am J Obstet Gynecol. 1999;180(5):1196-1201. X-3. [pmid: 10329877].
524 Tomita H, et al. Stretching of the ductus: an important factor in determining the outcome of coil occlusion. Jpn Circ J. 1999;63(8):593-596. X-6. [pmid: 10478808].
525 Tseng JJ, et al. In utero diagnosis of cardiac hemangioma. Ultrasound Obstet Gynecol. 1999;13(5):363-365. X-5. [pmid: 10380304].
526 Uchiyama M, et al. Sacrococcygeal teratoma: a series of 19 cases with long-term follow-up. Eur J Pediatr Surg. 1999;9(3):158-162. X-6. [pmid: 10427491].
527 Urban BA, et al. Helical CT amniography of congenital diaphragmatic hernia. AJR Am J Roentgenol. 1999;172(3):809-812. X-6. [pmid: 10063887].
528 van Leeuwen K, et al. Prenatal diagnosis of congenital cystic adenomatoid malformation and its postnatal presentation, surgical indications, and natural history. J Pediatr Surg. 1999;34(5):794-798. discussion 798–799. X-6. [pmid: 10359183].
529 Weinzweig J, et al. The fetal cleft palate: II. Scarless healing after in utero repair of a congenital model. Plast Reconstr Surg. 1999;104(5):1356-1364. X-3. [pmid: 10513918].
530 Treatment of twin-twin transfusion syndrome (TTTS) with aggressive amnioreduction and/or fetoscopic laser therapy. Tecnologica MAP Suppl. 2000:34-37. X-1.
531 Agnew T. Before their time. Surgery on the unborn is a reality. But can it be justified when a baby’s life is not at risk. New Sci. 2000;166(2237):18-19. X-1. [pmid: 11902200].
532 Arena S, et al. A case of non-immune hydrops fetalis with congenital cystic adenomatoid malformation of the left lung in a twin. Minerva Pediatr. 2000;52(5–6):307-312. X-5. [pmid: 11085057].
533 Arenholtz J. A case of fetus-in-fetu. Radiol Technol. 2000;71(6):605. X-6. [pmid: 10923346].
534 Bannister CM. Suggested goals for intrauterine surgery for the repair of myelomeningoceles. Eur J Pediatr Surg. 2000;10(Suppl 1):42. X-1.
535 Brown R, Nicolaides K. Constriction band of the arm following insertion of a pleuro-amniotic shunt. Ultrasound Obstet Gynecol. 2000;15(5):439-440. X-5. [pmid: 10976490].
536 Bruner JP, Jarnagin BK, Reinisch L. Percutaneous laser ablation of fetal congenital cystic adenomatoid malformation: too little, too late. Fetal Diagn Ther. 2000;15(6):359-363. X-5. [pmid: 11111218].
537 Bui TH, et al. Successful EXIT (ex utero intrapartum treatment) procedure in a fetus diagnosed prenatally with congenital high-airway obstruction syndrome due to laryngeal atresia. Eur J Pediatr Surg. 2000;10(5):328-333. X-5. [pmid: 11194545].
538 Carpentieri DF, et al. Subdiaphragmatic pulmonary sequestration: a case report with review of the literature. J Perinatol. 2000;20(1):60-62. X-5. [pmid: 10693103].
539 Chiba T, et al. In utero repair of rectal atresia after complete resection of a sacrococcygeal teratoma. Fetal Diagn Ther. 2000;15(3):187-190. X-5. [pmid: 10782007].
540 Chiba Y. Fetal intervention. Ultrasound Med Biol. 2000;26(Suppl 1):S135-S136. X-1. [pmid: 10794898].
541 Coakley FV, et al. Normal and hypoplastic fetal lungs: volumetric assessment with prenatal single-shot rapid acquisition with relaxation enhancement MR imaging. Radiology. 2000;216(1):107-111. X-6. [pmid: 10887234].
542 Crane JM. Fetal bladder outlet obstruction caused by ureterocele. Obstet Gynecol. 2000;95(6 Pt 2):1040. X-5. [pmid: 10808027].
543 De Santis M, et al. Congenital cystic adenomatoid malformation of the lung: antenatal ultrasound findings and fetal-neonatal outcome. Fifteen years of experience. Fetal Diagn Ther. 2000;15(4):246-250. X-6. [pmid: 10867488].
544 Deprest JA, et al. Bipolar coagulation of the umbilical cord in complicated monochorionic twin pregnancy. Am J Obstet Gynecol. 2000;182(2):340-345. X-6. [pmid: 10694334].
545 Drake C. Internet resources for researching twin-to-twin transfusion syndrome. AORN J. 2000;71(4):894. 896. X-6. [pmid: 10806544].
546 Dyamenahalli U, et al. Isolated ductus arteriosus aneurysm in the fetus and infant: a multi-institutional experience. J Am Coll Cardiol. 2000;36(1):262-269. X-6. [pmid: 10898444].
547 Easley ME, Schon LC. Peripheral nerve vein wrapping for intractable lower extremity pain. Foot Ankle Int. 2000;21(6):492-500. X-6. [pmid: 10884109].
548 Farley CL, Cox LA, Long BW. Ultrasound and twin-twin transfusion syndrome. Radiol Technol. 2000;72(2):95-100. X-1. [pmid: 11109260].
549 Feldstein VA, et al. Twin-twin transfusion syndrome: the ‘Select’ procedure. Fetal Diagn Ther. 2000;15(5):257-261. X-5. [pmid: 10971077].
550 Galinkin JL, et al. Anesthesia for fetoscopic fetal surgery: twin reverse arterial perfusion sequence and twin-twin transfusions syndrome. Anesth Analg. 2000;91(6):1394-1397. X-5. [pmid: 11093987].
551 Goto M, et al. Sacrococcygeal teratoma with hydrops fetalis and bilateral hydronephrosis. J Perinat Med. 2000;28(5):414-418. X-5. [pmid: 11125934].
552 Graf JL, et al. Successful fetal sacrococcygeal teratoma resection in a hydropic fetus. J Pediatr Surg. 2000;35(10):1489-1491. X-5. [pmid: 11051157].
553 Graf JL, et al. Successful resuscitation during fetal surgery. J Pediatr Surg. 2000;35(9):1388-1389. X-5. [pmid: 10999709].
554 Grisaru-Granovsky S, et al. Mid-trimester thoracoamniotic shunting for the treatment of fetal primary pleural effusions in a twin pregnancy. a case report. Fetal Diagn Ther. 2000;15(4):209-211. X-5. [pmid: 10867480].
555 Guadalupi P, Spadoni I, Vanini V. Repair of hemitruncus with autologous arterial ring and valved bioconduit. Ann Thorac Surg. 2000;70(5):1708-1710. X-5, X-6. [pmid: 11093522].
556 Harnett MJ, Hurley R. Anesthesia for fetal intervention. Anesth Analg. 2000;91(2):500. X-5. [pmid: 10910885].
557 Holzbeierlein J, et al. The urodynamic profile of myelodysplasia in childhood with spinal closure during gestation. J Urol. 2000;164(4):1336-1339. X-6. [pmid: 10992409].
558 Irwin BH, Vane DW. Complications of intrauterine intervention for treatment of fetal obstructive uropathy. Urology. 2000;55(5):774. X-5. [pmid: 10792105].
559 Kabra M, et al. Fraser-cryptophthalmos syndrome. Indian J Pediatr. 2000;67(10):775-778. X-6. [pmid: 11105430].
560 Khadaroo RG, et al. Fetus-in-fetu presenting as cystic meconium peritonitis: diagnosis, pathology, and surgical management. J Pediatr Surg. 2000;35(5):721-723. X-5. [pmid: 10813334].
561 Koike T, et al. Severe hypoproteinemia in a fetus after pleuro-amniotic shunts with double-basket catheters for treatment of chylothorax. J Obstet Gynaecol Res. 2000;26(5):373-376. X-5. [pmid: 11147726].
562 Leeners B, et al. Prune-belly syndrome: therapeutic options including in utero placement of a vesicoamniotic shunt. J Clin Ultrasound. 2000;28(9):500-507. X-6. [pmid: 11056030].
563 Leistikow EA, et al. Isolated large third-trimester intracranial cyst on fetal ultrasound: fact or fiction. Pediatrics. 2000;106(4):844-848. X-6. [pmid: 11015533].
564 Lwakatare F, et al. Ultrafast fetal MR images of sacrococcygeal teratoma: a case report. Comput Med Imaging Graph. 2000;24(1):49-52. X-5. [pmid: 10739323].
565 Mangels KJ, et al. Fetal MRI in the evaluation of intrauterine myelomeningocele. Pediatr Neurosurg. 2000;32(3):124-131. X-6. [pmid: 10867558].
566 Matias A, Montenegro N, Areias JC. Anticipating twin-twin transfusion syndrome in monochorionic twin pregnancy. Is there a role for nuchal translucency and ductus venosus blood flow evaluation at 11–14 weeks. Twin Res. 2000;3(2):65-70. X-6. [pmid: 10918616].
567 Mauldin J. Prenatal diagnosis and fetal therapy--what lies in future. Indian J Pediatr. 2000;67(12):899-905. X-6. [pmid: 11262989].
568 Meslin EM. Of clones, stem cells, and children: issues and challenges in human research ethics. J Womens Health Gend Based Med. 2000;9(8):831-841. X-1. [pmid: 11074949].
569 Nicolini U, et al. A new approach to prenatal treatment of extralobar pulmonary sequestration. Prenat Diagn. 2000;20(9):758-760. X-5. [pmid: 11015708].
570 Okie S. Over the tiniest patients, big ethical questions: fetal surgery’s growing reach raises issues of need and risks. Washington Post. 2000:A1-A16. X-1. [pmid: 15793931].
571 Olutoye OO, et al. Prenatal diagnosis and management of congenital lobar emphysema. J Pediatr Surg. 2000;35(5):792-795. X-6. [pmid: 10813352].
572 Poutamo J, et al. Diagnosing fetal urinary tract abnormalities: benefits of MRI compared to ultrasonography. Acta Obstet Gynecol Scand. 2000;79(1):65-71. X-6. [pmid: 10646819].
573 Quintero RA, et al. Fetal hydrolaparoscopy and endoscopic cystotomy in complicated cases of lower urinary tract obstruction. Am J Obstet Gynecol. 2000;183(2):324-330. discussion 330–333. X-5. [pmid: 10942465].
574 Quintero RA, et al. Minimally invasive intraluminal tracheal occlusion in a human fetus with left congenital diaphragmatic hernia at 27 weeks’ gestation via direct fetal laryngoscopy. Prenat Neonat Med. 2000;5:134-140. X-4.
575 Quintero RA, et al. Successful in utero endoscopic ablation of posterior urethral valves: a new dimension in fetal urology. Urology. 2000;55(5):774. X-5. [pmid: 10792104].
576 Robinson JN, et al. Predictors of episiotomy use at first spontaneous vaginal delivery. Obstet Gynecol. 2000;96(2):214-218. X-6. [pmid: 10908765].
577 Sapin E, et al. Transabdominal amnioinfusion to avoid fetal demise and intestinal damage in fetuses with gastroschisis and severe oligohydramnios. J Pediatr Surg. 2000;35(4):598-600. X-6. [pmid: 10770390].
578 Schild RL, et al. Diagnosis of a fetal mesoblastic nephroma by 3D-ultrasound. Ultrasound Obstet Gynecol. 2000;15(6):533-536. X-5, X-6. [pmid: 11005125].
579 Schwarz RE, et al. A carcinoembryonic antigen-secreting adenocarcinoma arising within a retrorectal tailgut cyst: clinicopathological considerations. Am J Gastroenterol. 2000;95(5):1344-1347. X-5. [pmid: 10811351].
580 Simon EM, et al. Fast MR imaging of fetal CNS anomalies in utero. AJNR Am J Neuroradiol. 2000;21(9):1688-1698. X-6. [pmid: 11039352].
581 Sittig SE, Asay GF. Congenital cystic adenomatoid malformation in the newborn: two case studies and review of the literature. Respir Care. 2000;45(10):1188-1195. X-6. [pmid: 11054898].
582 Smith RP, et al. Pain and stress in the human fetus. Eur J Obstet Gynecol Reprod Biol. 2000;92(1):161-165. X-1. [pmid: 10986451].
583 Srinivasan S. Fetal echocardiography. Indian J Pediatr. 2000;67(7):515-521. X-6. [pmid: 10957837].
584 Stelnicki EJ, et al. Nerve dependency in scarless fetal wound healing. Plast Reconstr Surg. 2000;105(1):140-147. X-3. [pmid: 10626982].
585 Thorp JA, et al. Decompression of fetal cardiac tamponade caused by congenital capillary hemangioma of the pericardium. Obstet Gynecol. 2000;96(5 Pt 2):816-817. X-5. [pmid: 11094218].
586 van Gemert MJ, Umur A. Trends of discordant fetal growth in monochorionic twin pregnancies. Phys Med Biol. 2000;45(8):N85-N93. X-6. [pmid: 10958206].
587 Ward VM, Langford K, Morrison G. Prenatal diagnosis of airway compromise: EXIT (ex utero intra-partum treatment) and foetal airway surgery. Int J Pediatr Otorhinolaryngol. 2000;53(2):137-141. X-6. [pmid: 10906519].
588 Yasukochi S, Satomi G. Fetal diagnosis of common arterial trunk with interrupted aortic arch using color power Doppler angiography. Cardiol Young. 2000;10(1):54-56. X-5. [pmid: 10695543].
589 Austin JC, et al. Vesicoamniotic shunt in a female fetus with the prune belly syndrome. J Urol. 2001;166(6):2382. X-5. [pmid: 11696791].
590 Bartha JL, Comino-Delgado R. Fetal chylothorax response to maternal dietary treatment. Obstet Gynecol. 2001;97(5 Pt 2):820-823. X-5, X-6. [pmid: 11336766].
591 Bliton MJ, Zaner RM. Over the cutting edge: how ethics consultation illuminates the moral complexity of open-uterine fetal repair of spina bifida and patients’ decision making. J Clin Ethics. 2001;12(4):346-360. X-1. [pmid: 12026740].
592 Carr SR, Plevyak MP. Contemporary evaluation and management of twin-twin transfusion syndrome. Med Health R I. 2001;84(5):165-168. X-1. [pmid: 11392956].
593 Cheatham JP. Intervention in the critically ill neonate and infant with hypoplastic left heart syndrome and intact atrial septum. J Interv Cardiol. 2001;14(3):357-366. X-1, X-5. [pmid: 12053397].
594 Coakley FV. Role of magnetic resonance imaging in fetal surgery. Top Magn Reson Imaging. 2001;12(1):39-51. X-1, X-6. [pmid: 11215715].
595 Cooper R, et al. Endoscopic documentation of unintentional perforation of the dividing membrane during amnioreduction for twin-twin transfusion syndrome. Fetal Diagn Ther. 2001;16(2):101-104. X-5. [pmid: 11173957].
596 Domanovic D, Zavrsnik T, Vesel S. Autologous placental blood transfusion after a planned neonatal pacemaker implantation. Transfus Med. 2001;11(6):459-461. X-5, X-6. [pmid: 11851945].
597 Hamada H, et al. Successful treatment of primary fetal hydrothorax with hydrops by pleuroamniotic shunt placement. Arch Gynecol Obstet. 2001;265(1):53-54. X-5. [pmid: 11327096].
598 Han SJ, Hwang EH. The development of fetal surgery. Yonsei Med J. 2001;42(6):602-608. X-1. [pmid: 11754143].
599 Howe EG. Unicorns, Carravaggio, and fetal surgery. J Clin Ethics. 2001;12(4):333-345. X-1. [pmid: 12026739].
600 Izquierdo LA, et al. In utero demonstration of aberrant systemic blood supply in lung sequestration: a case report. Bol Asoc Med P R. 2001;93(1–12):32-34. X-5. [pmid: 12755074].
601 Jenkin G, et al. Physiological and regulatory roles of activin A in late pregnancy. Mol Cell Endocrinol. 2001;180(1–2):131-138. X-6. [pmid: 11451582].
602 Jolly M, et al. Interstitial laser: a new surgical technique for twin reversed arterial perfusion sequence in early pregnancy. BJOG. 2001;108(10):1098-1102. X-6. [pmid: 11702844].
603 Jouannic JM, et al. Successful intrauterine shunting of a sacrococcygeal teratoma (SCT) causing fetal bladder obstruction. Prenat Diagn. 2001;21(10):824-826. X-5. [pmid: 11746122].
604 Kamata S, et al. Operative management for sacrococcygeal teratoma diagnosed in utero. J Pediatr Surg. 2001;36(4):545-548. X-6. [pmid: 11283874].
605 Kashani AH, Hutchins GM. Meningeal-cutaneous relationships in anencephaly: evidence for a primary mesenchymal abnormality. Hum Pathol. 2001;32(5):553-558. X-6. [pmid: 11381375].
606 Kathary N, et al. MRI imaging of fetal neck masses with airway compromise: utility in delivery planning. Pediatr Radiol. 2001;31(10):727-731. X-6. [pmid: 11685443].
607 Kitano Y, et al. BAPS prize-1999: Lung growth induced by prenatal tracheal occlusion and its modifying factors: a study in the rat model of congenital diaphragmatic hernia. J Pediatr Surg. 2001;36(2):251-259. X-3. [pmid: 11172410].
608 Kohl T. Congenital heart disease. Mending the tiniest hearts. Lancet. 2001;358(Suppl):S17. X-1. [pmid: 11784566].
609 Levine D, et al. Progressive fetal bronchial obstruction caused by a bronchogenic cyst diagnosed using prenatal MR imaging. AJR Am J Roentgenol. 2001;176(1):49-52. X-6. [pmid: 11133537].
610 Lipitz S, et al. A comparative study of multifetal pregnancy reduction from triplets to twins in the first versus early second trimesters after detailed fetal screening. Ultrasound Obstet Gynecol. 2001;18(1):35-38. X-6. [pmid: 11489223].
611 Longaker MT, et al. Fetal wound healing: progress report and future directions. Surgery. 2001;130(5):785-787. X-1. [pmid: 11685186].
612 Loo CK, et al. Cytologic findings in a fetal intracranial teratoma. A case report. Acta Cytol. 2001;45(2):227-232. X-5. [pmid: 11284308].
613 Lu GC, et al. Lethal pulmonary hypoplasia after in-utero myelomeningocele repair. Obstet Gynecol. 2001;98(4):698-701. X-5. [pmid: 11576591].
614 Luks FI. Fetal surgery. Med Health R I. 2001;84(5):169-170. X-1. [pmid: 11392957].
615 Luks FI, et al. Preoperative planning with magnetic resonance imaging and computerized volume rendering in twin-to-twin transfusion syndrome. Am J Obstet Gynecol. 2001;185(1):216-219. X-6. [pmid: 11483931].
616 Lyerly AD, et al. Attitudes of maternal-fetal specialists concerning maternal-fetal surgery. Am J Obstet Gynecol. 2001;185(5):1052-1058. X-6. [pmid: 11717632].
617 Mavroudis C, Backer CL. Surgical management of severe truncal insufficiency: experience with truncal valve remodeling techniques. Ann Thorac Surg. 2001;72(2):396-400. X-6. [pmid: 11515873].
618 McBride ME, et al. Hypogammaglobulinemia complicating chylothorax after cardiac surgery in two infants. J Cardiothorac Vasc Anesth. 2001;15(3):358-361. X-6. [pmid: 11426370].
619 Midrio P, et al. EXIT procedure in a twin gestation and review of the literature. Am J Perinatol. 2001;18(7):357-362. X-5, X-6. [pmid: 11731888].
620 Murphy DJ, et al. Ex-utero intrapartum treatment for cervical teratoma. BJOG. 2001;108(4):429-430. X-6. [pmid: 11305554].
621 Park HW. Embryological background for fetal surgery. Yonsei Med J. 2001;42(6):609-614. X-6. [pmid: 11754144].
622 Pumberger W, Moroder W, Wiesbauer P. Intraabdominal extralobar pulmonary sequestration exhibiting cystic adenomatoid malformation: prenatal diagnosis and characterization of a left suprarenal mass in the newborn. Abdom Imaging. 2001;26(1):28-31. X-5. [pmid: 11116355].
623 Quintero RA, et al. Selective photocoagulation of communicating vessels in the treatment of monochorionic twins with selective growth retardation. Am J Obstet Gynecol. 2001;185(3):689-696. X-6. [pmid: 11568799].
624 Quintero RA, et al. In-utero treatment of fetal bladder-outlet obstruction by a ureterocele. Lancet. 2001;357(9272):1947-1948. X-5. [pmid: 11425420].
625 Rypens F, et al. Fetal lung volume: estimation at MR imaging-initial results. Radiology. 2001;219(1):236-241. X-6. [pmid: 11274563].
626 Sbragia L, et al. Outcome of prenatally diagnosed solid fetal tumors. J Pediatr Surg. 2001;36(8):1244-1247. X-6. [pmid: 11479867].
627 Siu BL, et al. Aneurysmal dilatation of the ductus arteriosus in a neonate. Pediatr Cardiol. 2001;22(5):403-405. X-5. [pmid: 11526417].
628 Tseng JJ, Chou MM, Ho ES. In utero sonographic diagnosis of a communicating enteric duplication cyst in a giant omphalocele. Prenat Diagn. 2001;21(7):540-542. X-5. [pmid: 11494286].
629 Turgut F, et al. In utero MR imaging and management of foetal hydrocephalus and NTDs in the third trimester. J Neurosurg Sci. 2001;45(3):189-192. X-6. [pmid: 11731746].
630 Umur A, van Gemert MJ, Ross MG. Fetal urine and amniotic fluid in monochorionic twins with twin-twin transfusion syndrome: simulations of therapy. Am J Obstet Gynecol. 2001;185(4):996-1003. X-3. [pmid: 11641691].
631 Van Overmeire B, et al. Ibuprofen pharmacokinetics in preterm infants with patent ductus arteriosus. Clin Pharmacol Ther. 2001;70(4):336-343. X-6. [pmid: 11673749].
632 Wermenski K, et al. Prenatal diagnosis of a brain tumour--an example of diagnostic and therapeutical algorithm. Med Wieku Rozwoj. 2001;5(1):59-64. X-5. [pmid: 11276505].
633 Young BK, et al. Endoscopic ligation of umbilical cord at 19 week’s gestation in monoamniotic monochorionic twins discordant for hypoplastic left heart syndrome. Fetal Diagn Ther. 2001;16(1):61-64. X-5. [pmid: 11125255].
634 Antonelli PJ, et al. Fetal central auditory system metabolic response to cochlear implant stimulation. Otolaryngol Head Neck Surg. 2002;127(3):131-137. X-3, X-6. [pmid: 12297800].
635 Avni FE, et al. MR imaging of fetal sacrococcygeal teratoma: diagnosis and assessment. AJR Am J Roentgenol. 2002;178(1):179-183. X-6. [pmid: 11756117].
636 Axt-Fliedner R, et al. Prenatal diagnosis of sacrococcygeal teratoma: a review of cases between 1993 and 2000. Clin Exp Obstet Gynecol. 2002;29(1):15-18. X-6. [pmid: 12013082].
637 Berge SJ, et al. Natural history of 70 fetuses with a prenatally diagnosed orofacial cleft. Fetal Diagn Ther. 2002;17(4):247-251. X-6. [pmid: 12065955].
638 Boltshauser E, et al. Vanishing cerebellum in myelomeningocoele. Eur J Paediatr Neurol. 2002;6(2):109-113. X-6. [pmid: 11995957].
639 Bouchard S, et al. The EXIT procedure: experience and outcome in 31 cases. J Pediatr Surg. 2002;37(3):418-426. X-6. [pmid: 11877660].
640 Breysem L, et al. Postnatal cranial ultrasonographic findings in feto-fetal transfusion syndrome. Eur Radiol. 2002;12(12):2926-2932. X-6. [pmid: 12439572].
641 Cauldwell CB. Anesthesia for fetal surgery. Anesthesiol Clin North America. 2002;20(1):211-226. X-1. [pmid: 11892506].
642 Chan FY, et al. Limb constriction as a complication of intra-uterine vesico-amniotic shunt: fetoscopic release. Fetal Diagn Ther. 2002;17(5):315-320. X-5. [pmid: 12169819].
643 Chan KL, et al. Factors affecting outcomes of prenatally-diagnosed tumours. Prenat Diagn. 2002;22(5):437-443. X-6. [pmid: 12001204].
644 Chao AS, et al. Application of monopolar thermocoagulation in an acardiac fetus. Prenat Diagn. 2002;22(6):499-500. X-6. [pmid: 12116315].
645 Chen CP, et al. Sonographic findings in a case of congenital pyloric diaphragm. Ultrasound Obstet Gynecol. 2002;19(5):528-529. X-6. [pmid: 11982994].
646 Chervenak FA, McCullough LB. A comprehensive ethical framework for fetal research and its application to fetal surgery for spina bifida. Am J Obstet Gynecol. 2002;187(1):10-14. X-1. [pmid: 12114882].
647 Correia-Pinto J, et al. In utero meconium exposure increases spinal cord necrosis in a rat model of myelomeningocele. J Pediatr Surg. 2002;37(3):488-492. X-3. [pmid: 11877673].
648 Crombleholme TM, et al. Cystic adenomatoid malformation volume ratio predicts outcome in prenatally diagnosed cystic adenomatoid malformation of the lung. J Pediatr Surg. 2002;37(3):331-338. X-6. [pmid: 11877643].
649 De Paepe ME, et al. Demonstration of placental vascular anatomy in monochorionic twin gestations. Pediatr Dev Pathol. 2002;5(1):37-44. X-3. [pmid: 11815867].
650 Donofrio MT. Images in cardiovascular medicine. Premature closure of the foramen ovale and ductus arteriosus in a fetus with transposition of the great arteries. Circulation. 2002;105(11):e65-e66. X-5. [pmid: 11901055].
651 Eddleman KA, et al. Selective termination of anomalous fetuses in multifetal pregnancies: two hundred cases at a single center. Am J Obstet Gynecol. 2002;187(5):1168-1172. X-6. [pmid: 12439497].
652 Fesslova V, et al. Spectrum and outcome of atrioventricular septal defect in fetal life. Cardiol Young. 2002;12(1):18-26. X-6. [pmid: 11922436].
653 Frader JE. Surgical fetal interventions: innovation and research. Account Res. 2002;9(3–4):193-198. X-1. [pmid: 12816127].
654 Fundaro C, et al. Myelomeningocele in a child with intrauterine exposure to efavirenz. AIDS. 2002;16(2):299-300. X-5, X-6. [pmid: 11807320].
655 Futagi Y, et al. Neurodevelopmental outcome in children with fetal hydrocephalus. Pediatr Neurol. 2002;27(2):111-116. X-6. [pmid: 12213611].
656 Gatti JM, Kirsch AJ, Massad CA. Antenatal intervention: jeopardizing life or limb?. Urology. 2002;60(4):697. X-5. [pmid: 12385940].
657 Henrich W, et al. Prenatal sonographic findings of thalamic cavernous angioma. Ultrasound Obstet Gynecol. 2002;19(5):518-522. X-5, X-6. [pmid: 11982990].
658 Herndon CD, Casale AJ. Early second trimester intervention in a surviving infant with postnatally diagnosed urethral atresia. J Urol. 2002;168(4 Pt 1):1532-1533. X-5. [pmid: 12352452].
659 Howell LJ, et al. Management of fetal airway obstruction: an innovative strategy. MCN Am J Matern Child Nurs. 2002;27(4):238-243. X-5. [pmid: 12131276].
660 Hutson JM. 35th annual meeting of the pacific association of pediatric surgeons. J Pediatr Surg. 2002;37(12):1775. X-1. [pmid: 12483655].
661 Jesudason EC. Challenging embryological theories on congenital diaphragmatic hernia: future therapeutic implications for paediatric surgery. Ann R Coll Surg Engl. 2002;84(4):252-259. X-3. [pmid: 12215028].
662 Kazez A, et al. Sacrococcygeal heart: a very rare differentiation in teratoma. Eur J Pediatr Surg. 2002;12(4):278-280. X-5, X-6. [pmid: 12369008].
663 Lam YH, Tang MH, Shek TW. Thermocoagulation of fetal sacrococcygeal teratoma. Prenat Diagn. 2002;22(2):99-101. X-5. [pmid: 11857611].
664 Lenfant C. Report of the Task Force on Research in Pediatric Cardiovascular Disease. Circulation. 2002;106(9):1037-1042. X-1. [pmid: 12196324].
665 Leung EC, et al. Spinal lipoma misinterpreted as a meningomyelocele on antenatal MRI scan in a baby girl. Childs Nerv Syst. 2002;18(6–7):361-363. X-5. [pmid: 12172948].
666 Lurie S, Gur D, Glezerman M. Argon beam coagulation during caesarean section. BJOG. 2002;109(12):1415. X-6. [pmid: 12504984].
667 Machin GA. Rejoinder to meta-analysis of twin-twin transfusion by Skupski et al. Twin Res. 2002;5(1):5-7. X-1. [pmid: 11893275].
668 Midrio P, et al. Prenatal diagnosis of terminal myelocystocele in the fetal surgery era: case report. Neurosurgery. 2002;50(5):1152-1154. discussion 1154–1155. X-5. [pmid: 11950422].
669 Noah MM, et al. Short-term maternal outcomes that are associated with the EXIT procedure, as compared with cesarean delivery. Am J Obstet Gynecol. 2002;186(4):773-777. X-6. [pmid: 11967506].
670 Paek BW, et al. Successful fetal intervention for congenital high airway obstruction syndrome. Fetal Diagn Ther. 2002;17(5):272-276. X-5. [pmid: 12169810].
671 Pan HS, et al. Fetal meconium peritonitis in single and twin pregnancy. Two cases report. Arch Gynecol Obstet. 2002;266(4):229-231. X-6. [pmid: 12192485].
672 Petratos PB, et al. Ex vivo evaluation of human fetal membrane closure. Lasers Surg Med. 2002;30(1):48-53. X-3, X-5, X-6. [pmid: 11857604].
673 Quintero RA, et al. Fetoscopic demonstration of perimortem feto-fetal hemorrhage in twin-twin transfusion syndrome. Ultrasound Obstet Gynecol. 2002;20(6):638-639. X-5. [pmid: 12493060].
674 Quintero RA, et al. Operative fetoscopy via telesurgery. Ultrasound Obstet Gynecol. 2002;20(4):390-391. X-5. [pmid: 12383324].
675 Rakowski E. Who should pay for bad genes. Calif Law Rev. 2002;90(5):1345-1414. X-1. [pmid: 12436972].
676 Rintoul NE, et al. A new look at myelomeningoceles: functional level, vertebral level, shunting, and the implications for fetal intervention. Pediatrics. 2002;109(3):409-413. X-6. [pmid: 11875133].
677 Savulescu J. The embryonic stem cell lottery and the cannibalization of human beings. Bioethics. 2002;16(6):508-529. X-1. [pmid: 12472112].
678 Soothill P, et al. Ultrasound-guided, intra-abdominal laser to treat acardiac pregnancies. BJOG. 2002;109(3):352-354. X-6. [pmid: 11950194].
679 Suri V, et al. Pregnancy in a noncommunicating horn of a unicornuate uterus with fetal salvage. Acta Obstet Gynecol Scand. 2002;81(5):473-474. X-5. [pmid: 12027825].
680 Sydorak RM, et al. Prenatal resection of a fetal pericardial teratoma. Fetal Diagn Ther. 2002;17(5):281-285. X-5. [pmid: 12169812].
681 Tashjian DB, Konefal SH. Hypertrophic pyloric stenosis in utero. Pediatr Surg Int. 2002;18(5–6):539-540. X-5, X-6. [pmid: 12415405].
682 Tsao K, et al. Selective reduction of acardiac twin by radiofrequency ablation. Am J Obstet Gynecol. 2002;187(3):635-640. X-6. [pmid: 12237640].
683 Tseng D, Curran TJ, Silen ML. Minimally invasive management of the prenatally torsed ovarian cyst. J Pediatr Surg. 2002;37(10):1467-1469. X-6. [pmid: 12378456].
684 Williams HJ, Johnson KJ. Imaging of congenital cystic lung lesions. Paediatr Respir Rev. 2002;3(2):120-127. X-1. [pmid: 12297058].
685 Afolabi IR. Sacrococcygeal teratoma: a case report and a review of literature. Pac Health Dialog. 2003;10(1):57-61. X-5, X-6. [pmid: 16276945].
686 Apfel HD. Fetal intervention: Halacha’s response to a new bioethical dilemma. J Halacha Contemporary Society. 2003(46):9-40. X-1. [pmid: 14696644].
687 Arzt W, et al. Invasive intrauterine treatment of pulmonary atresia/intact ventricular septum with heart failure. Ultrasound Obstet Gynecol. 2003;21(2):186-188. X-5. [pmid: 12601844].
688 Beuls E, et al. The Arnold-Chiari type II malformation at midgestation. Pediatr Neurosurg. 2003;39(3):149-158. X-5. [pmid: 12876395].
689 Beuls EA, et al. In vitro high-field magnetic resonance imaging-documented anatomy of a fetal myelomeningocele at 20 weeks’ gestation. A contribution to the rationale of intrauterine surgical repair of spina bifida. J Neurosurg. 2003;98(2 Suppl):210-214. X-5. [pmid: 12650407].
690 Bliton MJ. Ethics: “life before birth” and moral complexity in maternal-fetal surgery for spina bifida. Clin Perinatol. 2003;30(3):449-464. v. vi. X-1. [pmid: 14533888].
691 Bruner JP. In their footsteps: a brief history of maternal-fetal surgery. Clin Perinatol. 2003;30(3):439-447. X-1. [pmid: 14533887].
692 Budts W, Gewillig M, Van de Werf F. Left-to-right shunting in common congenital heart defects: which patients are eligible for percutaneous interventions. Acta Cardiol. 2003;58(3):199-205. X-1. [pmid: 12846509].
693 Cannon JW, et al. Real-time three-dimensional ultrasound for guiding surgical tasks. Comput Aided Surg. 2003;8(2):82-90. X-1. [pmid: 15015721].
694 Chan FY, et al. Fetal endoscopic telesurgery using an Internet Protocol connection: clinical and technical challenges. J Telemed Telecare. 2003;9(Suppl 2):S12-S14. X-3. [pmid: 14728749].
695 Chen CP, et al. Second-trimester evaluation of fetal sacrococcygeal teratoma using three-dimensional color Doppler ultrasound and magnetic resonance imaging. Prenat Diagn. 2003;23(7):602-603. X-6. [pmid: 12868095].
696 Chervenak FA, McCullough LB. An ethical framework for fetal research. Med Ethics. 2003;10(1):1-2. X-1.
697 Christensen G, et al. Embryonic and neonatal cardiac gene transfer in vivo. Methods Mol Biol. 2003;219:169-178. X-3. [pmid: 12597007].
698 Eckoldt F, et al. Meconium peritonitis and pseudo-cyst formation: prenatal diagnosis and post-natal course. Prenat Diagn. 2003;23(11):904-908. X-6. [pmid: 14634976].
699 Farmer DL, Hirose S. Fetal intervention for complications of monochorionic twinning. World J Surg. 2003;27(1):103-107. X-1. [pmid: 12557045].
700 Fesslova V, Villa L, Kustermann A. Long-term experience with the prenatal diagnosis of cardiac anomalies in high-risk pregnancies in a tertiary center. Ital Heart J. 2003;4(12):855-864. X-6. [pmid: 14976850].
701 Ford NM. Fetal surgery: the wisdom of Solomon. Ethics Medics. 2003;28(8):3-4. X-1. [pmid: 16206472].
702 Fujiki Y, et al. Successful multilineage engraftment of human cord blood cells in pigs after in utero transplantation. Transplantation. 2003;75(7):916-922. X-3. [pmid: 12698074].
703 Gallot D, Laurichesse H, Lemery D. Selective feticide in monochorionic twin pregnancies by ultrasound-guided umbilical cord occlusion. Ultrasound Obstet Gynecol. 2003;22(5):484-488. X-6. [pmid: 14618661].
704 George TM, Cummings TJ. The immunohistochemical profile of the myelomeningocele placode: is the placode normal. Pediatr Neurosurg. 2003;39(5):234-239. X-3. [pmid: 14512686].
705 Goodwin RP. Two craniotomy arguments don’t make it. J Med Philos. 2003;28(1):79-88. X-1. [pmid: 12715282].
706 Graf JL, Albanese CT. Fetal sacrococcygeal teratoma. World J Surg. 2003;27(1):84-86. X-1. [pmid: 12557042].
707 Grebille AG, et al. Pericardial teratoma complicated by hydrops: successful fetal therapy by thoracoamniotic shunting. Prenat Diagn. 2003;23(9):735-739. X-5. [pmid: 12975784].
708 Groves A, Cameron H, Barrett M. Intra-abdominal lymphangioma: further images of prenatal diagnosis. Ultrasound Obstet Gynecol. 2003;22(1):97-98. X-6. [pmid: 12858314].
709 Harrison MR. Fetal surgery: trials, tribulations, and turf. J Pediatr Surg. 2003;38(3):275-282. X-1. [pmid: 12632335].
710 Hata N, et al. Three-dimensional volume rendering of fetal MR images for the diagnosis of congenital cystic adenomatoid malformation. Acad Radiol. 2003;10(3):309-312. X-5, X-6. [pmid: 12643560].
711 Hedrick HL. Ex utero intrapartum therapy. Semin Pediatr Surg. 2003;12(3):190-195. X-6. [pmid: 12961113].
712 Herini E, et al. Clinical features of infants with subependymal germinolysis and choroid plexus cysts. Pediatr Int. 2003;45(6):692-696. X-6. [pmid: 14651543].
713 Hirose S, Farmer DL. Fetal surgery for sacrococcygeal teratoma. Clin Perinatol. 2003;30(3):493-506. X-1. [pmid: 14533891].
714 Ho NK. Neonatology in Singapore: the way we were, the way forward. Ann Acad Med Singapore. 2003;32(3):311-317. X-1. [pmid: 12854374].
715 Ibrahim D, et al. Newborn with an open posterior hip dislocation and sciatic nerve injury after intrauterine radiofrequency ablation of a sacrococcygeal teratoma. J Pediatr Surg. 2003;38(2):248-250. X-5. [pmid: 12596115].
716 Kolas T, et al. Indications for cesarean deliveries in Norway. Am J Obstet Gynecol. 2003;188(4):864-870. X-6. [pmid: 12712077].
717 Lam H, Yates R, Jauniaux E. Successful early in utero management of fetal hydrothorax in a twin pregnancy. Prenat Diagn. 2003;23(3):221-224. X-5. [pmid: 12627423].
718 Lim FY, et al. Congenital high airway obstruction syndrome: natural history and management. J Pediatr Surg. 2003;38(6):940-945. X-6. [pmid: 12778398].
719 Lowenstein L, et al. In utero diagnosis of bladder perforation with urinary ascites. A case report. Fetal Diagn Ther. 2003;18(3):179-182. X-5. [pmid: 12711873].
720 Lyerly AD, Mahowald MB. Maternal-fetal surgery for treatment of myelomeningocele. Clin Perinatol. 2003;30(1):155-165. X-1. [pmid: 12696793].
721 Lyon HM, Holmes LB, Huang T. Multiple congenital anomalies associated with in utero exposure of phenytoin: possible hypoxic ischemic mechanism. Birth Defects Res A Clin Mol Teratol. 2003;67(12):993-996. X-5. [pmid: 14745921].
722 Markhardt BK, Farmer DL, Filly RA. Presumptive intrahepatic congenital cystic adenomatoid malformation. J Ultrasound Med. 2003;22(5):531-536. X-5. [pmid: 12751866].
723 Markov D, Jacquemyn Y, Leroy Y. Bilateral cleft lip and palate associated with increased nuchal translucency and maternal cocaine abuse at 14 weeks of gestation. Clin Exp Obstet Gynecol. 2003;30(2–3):109-110. X-5, X-6. [pmid: 12854855].
724 Michel-Behnke I, et al. Stenting of the ductus arteriosus and banding of the pulmonary arteries: basis for various surgical strategies in newborns with multiple left heart obstructive lesions. Heart. 2003;89(6):645-650. X-6. [pmid: 12748222].
725 Noia G, et al. A novel route of transplantation of human cord blood stem cells in preimmune fetal sheep: the intracelomic cavity. Stem Cells. 2003;21(6):638-646. X-3, X-6. [pmid: 14595123].
726 Oepkes D, et al. Congenital high airway obstruction syndrome successfully managed with ex-utero intrapartum treatment. Ultrasound Obstet Gynecol. 2003;22(4):437-439. X-5, X-6. [pmid: 14528485].
727 Oi S. Diagnosis, outcome, and management of fetal abnormalities: fetal hydrocephalus. Childs Nerv Syst. 2003;19(7–8):508-516. X-6. [pmid: 12920541].
728 Oi S. Current status of prenatal management of fetal spina bifida in the world: worldwide cooperative survey on the medico-ethical issue. Childs Nerv Syst. 2003;19(7–8):596-599. X-1. [pmid: 12905004].
729 Pierre-Kahn A, Sonigo P. Lumbosacral lipomas: in utero diagnosis and prognosis. Childs Nerv Syst. 2003;19(7–8):551-554. X-6. [pmid: 12820003].
730 Reitsma AM, Moreno JD. Maternal-fetal research and human research protections policy. Clin Perinatol. 2003;30(1):141-153. X-1. [pmid: 12696792].
731 Rosen MA, Andreae MH, Cameron AG. Nitroglycerin for fetal surgery: fetoscopy and ex utero intrapartum treatment procedure with malignant hyperthermia precautions. Anesth Analg. 2003;96(3):698-700. table of contents. X-5, X-6. [pmid: 12598248].
732 Salomon LJ, et al. Fetal thoracoamniotic shunting as the only treatment for pulmonary sequestration with hydrops: favorable long-term outcome without postnatal surgery. Ultrasound Obstet Gynecol. 2003;21(3):299-301. X-5. [pmid: 12666228].
733 Schmidt S, et al. Operative fetoscopical management of intrauterine obstructive uropathia by urethral stent. J Perinat Med. 2003;31(4):313-316. X-5. [pmid: 12951887].
734 Senat MV, et al. The value of middle cerebral artery peak systolic velocity in the diagnosis of fetal anemia after intrauterine death of one monochorionic twin. Am J Obstet Gynecol. 2003;189(5):1320-1324. X-6. [pmid: 14634562].
735 Sepulveda W, Corral E, Gutierrez J. A simple device for vascular occlusion of acardiac twins. Ultrasound Obstet Gynecol. 2003;21(4):386-388. X-6. [pmid: 12704749].
736 Sinha A, Sarin YK, Sengar M. Magnetic Resonance Imaging (MRI) in the diagnosis of fetus-in-fetu. Indian Pediatr. 2003;40(1):63-64. X-6. [pmid: 12554923].
737 Sonigo-Cohen P, et al. Prenatal diagnosis of diastematomyelia. Childs Nerv Syst. 2003;19(7–8):555-560. X-6. [pmid: 12845458].
738 Soothill PW, Bartha JL, Tizard J. Ultrasound-guided laser treatment for fetal bladder outlet obstruction resulting from ureterocele. Am J Obstet Gynecol. 2003;188(4):1107-1108. X-5. [pmid: 12712121].
739 Stanley JD. Fetal surgery and wrongful death actions on behalf of the unborn: an argument for a social standard. Vanderbilt Law Rev. 2003;56(5):1523-1555. X-1. [pmid: 15568242].
740 Sutton LN, Adzick NS, Johnson MP. Fetal surgery for myelomeningocele. Childs Nerv Syst. 2003;19(7–8):587-591. X-1. [pmid: 12879345].
741 Valla JS, et al. Congenital seminal vesicle cyst: prenatal diagnosis and postnatal laparoscopic excision with an attempt to preserve fertility. BJU Int. 2003;91(9):891-892. X-6. [pmid: 12780858].
742 Weinstein AS, Goldstein RB, Barkovich AJ. In utero disappearance of the corpus callosum secondary to extensive brain injury. J Ultrasound Med. 2003;22(8):837-840. X-6. [pmid: 12901413].
743 Young AJ, et al. Engraftment of human cord blood-derived stem cells in preimmune ovine fetuses after ultrasound-guided in utero transplantation. Am J Obstet Gynecol. 2003;189(3):698-701. X-3. [pmid: 14526296].
744 Berge SJ, et al. Diagnosis and management of cervical teratomas. Br J Oral Maxillofac Surg. 2004;42(1):41-45. X-6. [pmid: 14706299].
745 Burdis L, Koch DD. The use of cardiopulmonary bypass and extracorporeal membrane oxygenation for support during removal of two teratomas and hydrops fetalis. J Extra Corpor Technol. 2004;36(2):182-184. X-5. [pmid: 15334763].
746 Carr SR, et al. Antenatal necrotic injury in severe twin-to-twin transfusion syndrome. A case and review. Fetal Diagn Ther. 2004;19(4):370-372. X-5. [pmid: 15192299].
747 Chen CP, et al. Second-trimester diagnosis of complete trisomy 9 associated with abnormal maternal serum screen results, open sacral spina bifida and congenital diaphragmatic hernia, and review of the literature. Prenat Diagn. 2004;24(6):455-462. X-6. [pmid: 15229846].
748 Fieni S, et al. Twin-twin transfusion syndrome: a review of treatment option. Acta Biomed. 2004;75(Suppl 1):34-39. X-3. [pmid: 15301288].
749 Fountain-Dommer RR, et al. Outcome following, and impact of, prenatal identification of the candidates for the Norwood procedure. Cardiol Young. 2004;14(1):32-38. X-6. [pmid: 15237668].
750 Hamrick SE, Brook MM, Farmer DL. Fetal surgery for congenital diaphragmatic hernia and pulmonary sequestration complicated by postnatal diagnosis of transposition of the great arteries. Fetal Diagn Ther. 2004;19(1):40-42. X-5. [pmid: 14646416].
751 Harrison MR. The University of California at San Francisco Fetal Treatment Center: a personal perspective, Fetal Diagn Ther. 2004;19(6):513-524. X-1.
752 Hirose S, et al. The ex utero intrapartum treatment procedure: Looking back at the EXIT. J Pediatr Surg. 2004;39(3):375-380. discussion 375–380. X-6. [pmid: 15017555].
753 Hofmann R, et al. Fetoscopic placement of a transurethral stent for intrauterine obstructive uropathy. J Urol. 2004;171(1):384-386. X-5. [pmid: 14665937].
754 Hsu YR, Lee SY. Prenatal diagnosis of congenital cystic adenomatoid malformation. Chang Gung Med J. 2004;27(1):61-65. X-5, X-6. [pmid: 15074892].
755 Huber A, et al. Amniotic fluid and maternal blood characteristics in severe mid-trimester twin-twin transfusion syndrome. Fetal Diagn Ther. 2004;19(6):504-509. X-6. [pmid: 15539875].
756 Iqbal N, Durrani Z. Management of sacrococcygeal teratoma of the fetus. J Coll Physicians Surg Pak. 2004;14(8):506-507. X-5. [pmid: 15321048].
757 Isaacs H Jr. Perinatal (fetal and neonatal) germ cell tumors. J Pediatr Surg. 2004;39(7):1003-1013. X-6. [pmid: 15213888].
758 Kanbur NO, et al. Diastematomyelia: a case with familial aggregation of neural tube defects. ScientificWorld Journal. 2004;4:847-852. X-5. [pmid: 15452650].
759 Keller TM, et al. MR assessment of fetal lung development using lung volumes and signal intensities. Eur Radiol. 2004;14(6):984-989. X-6. [pmid: 15014973].
760 Kuroda T, et al. Prenatal diagnosis and management of abdominal diseases in pediatric surgery. J Pediatr Surg. 2004;39(12):1819-1822. X-6. [pmid: 15616940].
761 Meyns B, et al. The Contegra conduit in the right ventricular outflow tract induces supravalvular stenosis. J Thorac Cardiovasc Surg. 2004;128(6):834-840. X-6. [pmid: 15573067].
762 Miller TE, et al. Recurrent third-trimester fetal loss and maternal mosaicism for long-QT syndrome. Circulation. 2004;109(24):3029-3034. X-5, X-6. [pmid: 15184283].
763 Neubert S, et al. Sonographic prognostic factors in prenatal diagnosis of SCT. Fetal Diagn Ther. 2004;19(4):319-326. X-6. [pmid: 15192290].
764 Noia G, et al. The intracoelomic route: a new approach for in utero human cord blood stem cell transplantation. Fetal Diagn Ther. 2004;19(1):13-22. X-3. [pmid: 14646412].
765 Ogle BM, et al. Spontaneous fusion of cells between species yields transdifferentiation and retroviral transfer in vivo. FASEB J. 2004;18(3):548-550. X-6. [pmid: 14715691].
766 Okada T, et al. Postnatal management for prenatally diagnosed choledochal cysts. J Pediatr Surg. 2004;39(7):1055-1058. X-6. [pmid: 15213898].
767 Omeroglu S, et al. Intrauterine structure of foot muscles in talipes equinovarus due to high-level myelomeningocele: a light microscopic study in fetal cadavers. J Pediatr Orthop B. 2004;13(4):263-267. X-6. [pmid: 15199283].
768 Peek GJ, Elliott MJ. Fetal surgery for congenital diaphragmatic hernia. Pediatrics. 2004;113(6):1810-1811. X-1. [pmid: 15173511].
769 Picone O, et al. Thoracoamniotic shunting for fetal pleural effusions with hydrops. Am J Obstet Gynecol. 2004;191(6):2047-2050. X-6. [pmid: 15592290].
770 Pirovano S, et al. Mutations of the T-cell receptor constant region after in utero stem cell transplantation. Immunogenetics. 2004;56(3):214-219. X-6. [pmid: 15138733].
771 Porreco RP. Percutaneous ultrasonographically guided ablation of an acardiac twin. Am J Obstet Gynecol. 2004;190(2):572-574. X-5. [pmid: 14981412].
772 Preciado DA, et al. Intrapartum management of severe fetal airway obstruction. J Otolaryngol. 2004;33(5):283-288. X-6. [pmid: 15931811].
773 Rushford MP, et al. Prenatal sonographic detection of meckel diverticulum in utero with postnatal radiologic and surgical confirmation. J Ultrasound Med. 2004;23(2):319-321. X-6. [pmid: 14992372].
774 Saito N, et al. Successful endovascular repair of an aneurysm of the ductus diverticulum with a branched stent graft: case report and review of literature. J Vasc Surg. 2004;40(6):1228-1233. X-5, X-6. [pmid: 15622379].
775 Sentilhes L, et al. Favourable outcome of a tight constriction band secondary to amniotic band syndrome. Prenat Diagn. 2004;24(3):198-201. X-5, X-6. [pmid: 15057953].
776 Sepulveda W, et al. Intrafetal alcohol chemosclerosis of acardiac twins: a multicenter experience. Fetal Diagn Ther. 2004;19(5):448-452. X-6. [pmid: 15305102].
777 Sepulveda W, et al. Successful sonographically guided laser ablation of a large acardiac twin at 26 weeks’ gestation. J Ultrasound Med. 2004;23(12):1663-1666. X-5. [pmid: 15557310].
778 Shevell T, et al. Radiofrequency ablation in a monochorionic twin discordant for fetal anomalies. Am J Obstet Gynecol. 2004;190(2):575-576. X-5. [pmid: 14981413].
779 Sival DA, et al. Neonatal loss of motor function in human spina bifida aperta. Pediatrics. 2004;114(2):427-434. X-6. [pmid: 15286226].
780 Sutton LN, Adzick NS. Fetal surgery for myelomeningocele. Clin Neurosurg. 2004;51:155-62. X-1. [pmid: 15571140].
781 Taylor MJ, Talbert D, Fisk NM. Pseudo-arterio-arterial anastomoses in twin-twin transfusion syndrome. Placenta. 2004;25(8–9):742-747. discussion 748–752. X-3. [pmid: 15450393].
782 Tworetzky W, Marshall AC. Fetal interventions for cardiac defects. Pediatr Clin North Am. 2004;51(6):1503-1513. vii. X-1, X-5. [pmid: 15561170].
783 Warner BW. What’s new in pediatric surgery. J Am Coll Surg. 2004;199(2):273-285. X-1. [pmid: 15275885].
784 Wax JR, et al. Gravid uterus exteriorization at cesarean delivery for prenatally diagnosed placenta previa-accreta. Am J Perinatol. 2004;21(6):311-313. X-6. [pmid: 15311365].
785 Weisz B, et al. Tailored management of twin reversed arterial perfusion (TRAP) sequence. Ultrasound Obstet Gynecol. 2004;23(5):451-455. X-6. [pmid: 15133794].
786 Wright JD, et al. Prenatally diagnosed human caudal appendage: a case report. J Reprod Med. 2004;49(7):566-568. X-5. [pmid: 15305830].
787 Respecting women’s rights and fetal value: reflections on the question of fetal anesthesia. Conscience. 2005;26(3):39-40. X-1.
788 Adama van Scheltema PN, et al. Biochemical composition of amniotic fluid in pregnancies complicated with twin-twin transfusion syndrome. Fetal Diagn Ther. 2005;20(3):186-189. X-6. [pmid: 15824495].
789 Al-Ojaimi EH. Successful intrauterine aspiration of a large fetal ovarian cyst. Saudi Med J. 2005;26(2):308-310. X-5. [pmid: 15770312].
790 Asabe K, Oka Y, Shirakusa T. Fetal case of congenital cystic adenomatoid malformation of the lung: fetal therapy and a review of the published reports in Japan. Congenit Anom (Kyoto). 2005;45(3):96-101. X-5. [pmid: 16131368].
791 Berg C, et al. The syndrome of left isomerism: sonographic findings and outcome in prenatally diagnosed cases. J Ultrasound Med. 2005;24(7):921-931. X-6. [pmid: 15972706].
792 Bliton MJ. Parental hope confronting scientific uncertainty: a test of ethics in maternal-fetal surgery for spina bifida. Clin Obstet Gynecol. 2005;48(3):595-607. X-6. [pmid: 16012227].
793 Brumfield SS, Fausett MB, Fries MH. Intrauterine fetal resuscitation following complications of closed fetal surgery. Fetal Diagn Ther. 2005;20(4):272-274. X-5. [pmid: 15980639].
794 Celiker A, et al. Transcatheter closure of patent ductus arteriosus with Nit-Occlud coils. Catheter Cardiovasc Interv. 2005;65(4):569-576. X-6. [pmid: 15973674].
795 Chen CP, et al. Prenatal magnetic resonance imaging demonstration of the systemic feeding artery of a pulmonary sequestration associated with in utero regression. Prenat Diagn. 2005;25(8):721-723. X-6. [pmid: 16049993].
796 Chescheir NC, D’Alton M. Evidence-based medicine and fetal treatment: how to get involved. Obstet Gynecol. 2005;106(3):610-613. X-1. [pmid: 16135596].
797 Chescheir NC, Socol M. The National Institutes of Health Workshop on Fetal Treatment: needs assessment and future directions, Obstet Gynecol. 2005;106(4):828-833. X-1.
798 Chua JH, et al. Fetus-in-fetu in the pelvis: report of a case and literature review. Ann Acad Med Singapore. 2005;34(10):646-649. X-5, X-6. [pmid: 16382253].
799 Cohen-Overbeek TE, et al. Mild renal pyelectasis in the second trimester: determination of cut-off levels for postnatal referral. Ultrasound Obstet Gynecol. 2005;25(4):378-383. X-6. [pmid: 15791623].
800 Comparetto C, et al. Fetal and neonatal ovarian cysts: what’s their real meaning. Clin Exp Obstet Gynecol. 2005;32(2):123-125. X-6. [pmid: 16108397].
801 Cortes RA, et al. Pre-emptive placement of a presealant for amniotic access. Am J Obstet Gynecol. 2005;193(3 Pt 2):1197-1203. X-6. [pmid: 16157137].
802 Cunat V, et al. Congenital diaphragmatic hernia associated with esophageal atresia, tracheoesophageal fistula, and truncus arteriosus in a premature newborn. Pediatr Surg Int. 2005;21(8):684-686. X-5, X-6. [pmid: 15933889].
803 del Rio M, et al. Successful selective termination at 17 weeks’ gestation in monochorionic monoamniotic twin pregnancy affected by twin-twin transfusion syndrome and discordant for hypoplastic left heart syndrome. Prenat Diagn. 2005;25(13):1223-1225. X-5. [pmid: 16353269].
804 El Kady D, et al. Congenital cardiac left ventricular aneurysm with pericardial effusion: early prenatal diagnosis and intervention. J Ultrasound Med. 2005;24(7):1011-1015. X-5, X-6. [pmid: 15972717].
805 Eschertzhuber S, et al. Verifying correct endotracheal intubation by measurement of end-tidal carbon dioxide during an ex utero intrapartum treatment procedure. Anesth Analg. 2005;101(3):658-660. table of contents. X-5, X-6. [pmid: 16115970].
806 Ewert P. Challenges encountered during closure of patent ductus arteriosus. Pediatr Cardiol. 2005;26(3):224-229. X-6. [pmid: 16082574].
807 Fayn E, et al. Ultrasonic biophysical measurements in the normal human fetus for optimal design of the monolithic fetal pacemaker. Am J Cardiol. 2005;95(10):1267-1270. X-6. [pmid: 15878011].
808 Galili O, Mogilner J. Type IV sacrococcygeal teratoma causing urinary retention: a rare presentation. J Pediatr Surg. 2005;40(2):E18-E20. X-5. [pmid: 15750911].
809 Gardiner HM, et al. Images in cardiovascular medicine. Pericardiocentesis at 14 weeks: effective treatment of pericardial effusion complicating right ventricular diverticulum. Circulation. 2005;112(9):e120. X-5. [pmid: 16129806].
810 Gezer A, Simsek YO, Gani H. Elective cesarean section for preterm intrauterine growth retarded fetuses. Int J Gynaecol Obstet. 2005;88(2):138-139. X-6. [pmid: 15694089].
811 Gonzalez-Abreu EE. Parental voices: For Angeline: A mother’s reflection and emotional struggle with the loss of a typical child and how she stumbles into an unexpected world of special needs and the people who live there. Clin Obstet Gynecol. 2005;48(3):518-526. X-1. [pmid: 16012220].
812 Gonzalez-Abreu MM. Parental voices: You get what you get and you don’t get upset: a child’s answer to life’s biggest challenges. Clin Obstet Gynecol. 2005;48(3):527-533. X-1. [pmid: 16012221].
813 Hedrick HL, et al. The ex utero intrapartum therapy procedure for high-risk fetal lung lesions. J Pediatr Surg. 2005;40(6):1038-1043. discussion 1044. X-6. [pmid: 15991193].
814 Huisman TA, et al. Magnetic resonance imaging of the feto-placentar unit after fetoscopic laser coagulation for twin-to-twin transfusion syndrome. Acta Radiol. 2005;46(3):328-330. X-1. [pmid: 15981732].
815 Illanes S, et al. Prenatal diagnosis of echogenic lung: evolution and outcome. Ultrasound Obstet Gynecol. 2005;26(2):145-149. X-6. [pmid: 15988784].
816 Jung E, et al. Successful outcome following prenatal intervention in a female fetus with bladder outlet obstruction. Prenat Diagn. 2005;25(12):1107-1110. X-5. [pmid: 16231298].
817 Kanamori Y, et al. A case of intrapericardial diaphragmatic hernia with a massive pericardial effusion: fetal diagnosis and therapy. J Pediatr Surg. 2005;40(11):e43-e55. X-5. [pmid: 16291140].
818 Kennedy D, Kennedy L. Parental voices: our journey of grace. Clin Obstet Gynecol. 2005;48(3):534-539. X-1. [pmid: 16012222].
819 Kim SK, et al. Successful vesicoamniotic shunting of posterior urethral valves in the first trimester of pregnancy. Ultrasound Obstet Gynecol. 2005;26(6):666-668. X-5. [pmid: 16254891].
820 Kim YT, et al. Treatment of congenital cystic adenomatoid malformation-does resection in the early postnatal period increase surgical risk. Eur J Cardiothorac Surg. 2005;27(4):658-661. X-6. [pmid: 15784369].
821 Kinnick V. Twin-to-twin transfusion syndrome. AWHONN Lifelines. 509. 2005;9(6):512-511. X-1, X-5. [pmid: 16480236].
822 Kohl T, et al. Fetal transesophageal echocardiography: clinical introduction as a monitoring tool during cardiac intervention in a human fetus. Ultrasound Obstet Gynecol. 2005;26(7):780-785. X-5. [pmid: 16273589].
823 Kolditz DP, et al. Low-energy radiofrequency catheter ablation as therapy for supraventricular tachycardia in a premature neonate. Eur J Pediatr. 2005;164(9):559-562. X-5. [pmid: 15889275].
824 Leung WC, et al. Unexpected intrauterine death following resolution of hydrops fetalis after betamethasone treatment in a fetus with a large cystic adenomatoid malformation of the lung. Ultrasound Obstet Gynecol. 2005;25(6):610-612. X-5. [pmid: 15912480].
825 Leva E, et al. The role of the surgeon in the case of a giant neck mass in the EXIT procedure. J Pediatr Surg. 2005;40(4):748-750. X-6. [pmid: 15852298].
826 Lonjon M, et al. Prenatal diagnosis of a craniopharyngioma: a new case with radical surgery and review. Childs Nerv Syst. 2005;21(3):177-180. X-5, X-6. [pmid: 15290187].
827 Lyons A. Parental voices: One father’s thoughts on fetal surgery. Clin Obstet Gynecol. 2005;48(3):540-547. X-1. [pmid: 16012223].
828 Matias A, Ramalho C, Montenegro N. Search for hemodynamic compromise at 11–14 weeks in monochorionic twin pregnancy: is abnormal flow in the ductus venosus predictive of twin-twin transfusion syndrome. J Matern Fetal Neonatal Med. 2005;18(2):79-86. X-6. [pmid: 16203591].
829 McAuliffe FM, et al. Cardiac diverticulum with pericardial effusion: report of two new cases treated by in-utero pericardiocentesis and a review of the literature. Ultrasound Obstet Gynecol. 2005;25(4):401-404. X-6. [pmid: 15747327].
830 McCullough LB, Coverdale JH, Chervenak FA. A comprehensive ethical framework for responsibly designing and conducting pharmacologic research that involves pregnant women. Am J Obstet Gynecol. 2005;193(3 Pt 2):901-907. X-6. [pmid: 16157085].
831 Merchant AM, et al. Management of fetal mediastinal teratoma. J Pediatr Surg. 2005;40(1):228-231. X-5. [pmid: 15868589].
832 Mittermayer C, et al. Prenatal magnetic resonance imaging as a useful adjunctive to ultrasound-enhanced diagnosis in case of a giant foetal tumour of the neck. Ultraschall Med. 2005;26(1):46-50. X-6. [pmid: 15700228].
833 Mohammadi S, et al. Surgery for right ventricle to pulmonary artery conduit obstruction: risk factors for further reoperation. Eur J Cardiothorac Surg. 2005;28(2):217-222. X-6. [pmid: 15967672].
834 Prefumo F, et al. Fetal congenital cardiac diverticulum with pericardial effusion: two cases with different presentations in the first trimester of pregnancy. Ultrasound Obstet Gynecol. 2005;25(4):405-408. X-6. [pmid: 15747330].
835 Quintero RA, et al. In utero cardiac fetal surgery: laser atrial septotomy in the treatment of hypoplastic left heart syndrome with intact atrial septum. Am J Obstet Gynecol. 2005;193(4):1424-1428. X-5. [pmid: 16202736].
836 Quintero RA, et al. Management of twin-twin transfusion syndrome in pregnancies with iatrogenic detachment of membranes following therapeutic amniocentesis and the role of interim amniopatch. Ultrasound Obstet Gynecol. 2005;26(6):628-633. X-6. [pmid: 16217744].
837 Rahbar R, et al. Fetal surgery in otolaryngology: a new era in the diagnosis and management of fetal airway obstruction because of advances in prenatal imaging. Arch Otolaryngol Head Neck Surg. 2005;131(5):393-398. X-6. [pmid: 15897417].
838 Ramdas A, Chopra R. FNAC diagnosis of a pre-sacral chordoma: a case report. Indian J Pathol Microbiol. 2005;48(2):250-251. X-5. [pmid: 16758685].
839 Rothschild BB, Estroff SE, Churchill LR. The cultural calculus of consent. Clin Obstet Gynecol. 2005;48(3):574-594. X-1. [pmid: 16012226].
840 Saitoh A, et al. Myelomeningocele in an infant with intrauterine exposure to efavirenz. J Perinatol. 2005;25(8):555-556. X-5, X-6. [pmid: 16047034].
841 Sikkel E, et al. Fetal cardiac contractility before and after intrauterine transfusion. Ultrasound Obstet Gynecol. 2005;26(6):611-617. X-6. [pmid: 16254879].
842 Stewart DL, Cook LN. Current management of congenital diaphragmatic hernia. J Ky Med Assoc. 2005;103(2):47-53. X-6. [pmid: 15751455].
843 Talabani H, et al. Fetal anal incontinence evaluated by amniotic fluid digestive enzyme assay in myelomeningocele spina bifida. Pediatr Res. 2005;58(4):766-770. X-6. [pmid: 16189207].
844 van den Wijngaard JP, et al. Simulation of therapy in a model of a nonhydropic and hydropic recipient in twin-twin transfusion syndrome. Am J Obstet Gynecol. 2005;193(6):1972-1980. X-3. [pmid: 16325599].
845 von Koch CS, et al. Myelomeningocele: characterization of a surgically induced sheep model and its central nervous system similarities and differences to the human disease. Am J Obstet Gynecol. 2005;193(4):1456-1462. X-3. [pmid: 16202740].
846 Wasant P, Sathienkijkanchai A. Neural tube defects at Siriraj Hospital, Bangkok, Thailand—10 years review 1990–1999. J Med Assoc Thai. 2005;88(Suppl 8):S92-S99. X-6. [pmid: 16858850].
847 Wilkins-Haug LE, et al. In-utero intervention for hypoplastic left heart syndrome—a perinatologist’s perspective. Ultrasound Obstet Gynecol. 2005;26(5):481-486. X-1. [pmid: 16184508].
848 Williamson J, Williamson S. Parental voices: the positive impact of medical professionals. Clin Obstet Gynecol. 2005;48(3):512-517. X-1. [pmid: 16012219].
849 Young BK, et al. Combined sonographic and endoscopic umbilical cord occlusion in twin and triplet gestations. J Perinat Med. 2005;33(6):530-533. X-6. [pmid: 16318617].
850 Zaner RM. Parental voices: Randal Lewis Morris was born. Clin Obstet Gynecol. 2005;48(3):548-561. X-1. [pmid: 16012224].
851 Zeng F, et al. Identification and characterization of engrafted human cells in human/goat xenogeneic transplantation chimerism. DNA Cell Biol. 2005;24(7):403-409. X-3, X-6. [pmid: 16008509].
852 Zhang P, et al. Fetal laryngeal stenosis/atresia and congenital high airway obstructive syndrome (CHAOS): a case report. J Perinatol. 2005;25(6):426-428. X-5, X-6. [pmid: 15843811].
853 Ames WA, et al. Long-term use of the laryngeal mask airway in a neonate. Anesth Analg. 2006;103(3):792. X-6. [pmid: 16931715].
854 Ayzen M, et al. Monochorionic twin gestation complicated by a sacrococcygeal teratoma with hydrops--optimal timing of delivery allows for survival of the unaffected twin. J Pediatr Surg. 2006;41(8):e11-e13. X-5. [pmid: 16863829].
855 Bader R, et al. Fetal pericardial teratoma: presentation of two cases and review of literature. Am J Perinatol. 2006;23(1):53-58. X-5. [pmid: 16450274].
856 Barini R, et al. Abruptio placentae during fetal myelomeningocele repair. Fetal Diagn Ther. 2006;21(1):115-117. X-5. [pmid: 16354988].
857 Basu A, et al. Fetus in fetu or differentiated teratomas. Indian J Pathol Microbiol. 2006;49(4):563-565. X-6. [pmid: 17183856].
858 Brown JW, et al. Valved bovine jugular vein conduits for right ventricular outflow tract reconstruction in children: an attractive alternative to pulmonary homograft. Ann Thorac Surg. 2006;82(3):909-916. X-6. [pmid: 16928507].
859 Chan DF, et al. Ex utero intrapartum treatment (EXIT) for congenital giant ranula. Acta Paediatr. 2006;95(10):1303-1305. X-6. [pmid: 16982507].
860 Chu GM, et al. Ex-utero intrapartum treatment: a controlled approach to the management of anticipated airway problems in the newborn. Hong Kong Med J. 2006;12(5):381-384. X-6. [pmid: 17028359].
861 Colmant C, et al. Second-trimester diagnosis of mucopolysaccharidosis type IV a presenting as hydrops fetalis. Prenat Diagn. 2006;26(8):750-752. X-6. [pmid: 16865740].
862 Danzer E, et al. Diagnosis and characterization of fetal sacrococcygeal teratoma with prenatal MRI. AJR Am J Roentgenol. 2006;187(4):W350-W356. X-6. [pmid: 16985105].
863 Dogan OF, et al. Spontaneous regression of left upper lobe emphysema after division of large ductus arteriosus in an infant. Turk J Pediatr. 2006;48(3):269-271. X-5, X-6. [pmid: 17172076].
864 Fujimura J, et al. Management of a suprasellar arachnoid cyst identified using prenatal sonography. J Clin Ultrasound. 2006;34(2):92-94. X-5, X-6. [pmid: 16547979].
865 Galindo A, et al. Pulmonary balloon valvuloplasty in a fetus with critical pulmonary stenosis/atresia with intact ventricular septum and heart failure. Fetal Diagn Ther. 2006;21(1):100-104. X-5. [pmid: 16354986].
866 Ghazi L, et al. Rapid growth of a fetal sacrococcygeal teratoma in an HIV-infected woman: a case report. J Reprod Med. 2006;51(5):431-434. X-5. [pmid: 16779993].
867 Gohlke BC, et al. Cord blood leptin and IGF-I in relation to birth weight differences and head circumference in monozygotic twins. J Pediatr Endocrinol Metab. 2006;19(1):3-9. X-6. [pmid: 16509522].
868 Hayashi S, et al. Manifestation of mirror syndrome after fetoscopic laser photocoagulation in severe twin-twin transfusion syndrome. Fetal Diagn Ther. 2006;21(1):51-54. X-5. [pmid: 16354975].
869 Hecher K, et al. Twin reversed arterial perfusion: fetoscopic laser coagulation of placental anastomoses or the umbilical cord. Ultrasound Obstet Gynecol. 2006;28(5):688-691. X-6. [pmid: 16958150].
870 Hinds R, et al. Variable degree of liver involvement in siblings with PiZZ alpha-1-antitrypsin deficiency-related liver disease. J Pediatr Gastroenterol Nutr. 2006;43(1):136-138. X-6. [pmid: 16819392].
871 Ishii K, et al. An experience of laser surgery for feto-fetal transfusion syndrome complicated with unexpected feto-fetal hemorrhage in a case of monochorionic triamniotic triplets. Fetal Diagn Ther. 2006;21(4):339-342. X-5. [pmid: 16757908].
872 Kaczmarek I, et al. Complete autologous reconstruction of the aorta and the pulmonary bifurcation in truncus arteriosus communis. Eur J Cardiothorac Surg. 2006;30(4):675-677. X-6. [pmid: 16893652].
873 Kim N, Friedberg MK, Silverman NH. Diagnosis and prognosis of fetuses with double outlet right ventricle. Prenat Diagn. 2006;26(8):740-745. X-6. [pmid: 16807954].
874 Koh CJ, et al. Bladder and external urethral sphincter function after prenatal closure of myelomeningocele. J Urol. 2006;176(5):2232-2236. X-6. [pmid: 17070301].
875 Kohl T, et al. Fetoscopic and ultrasound-guided decompression of the fetal trachea in a human fetus with Fraser syndrome and congenital high airway obstruction syndrome (CHAOS) from laryngeal atresia. Ultrasound Obstet Gynecol. 2006;27(1):84-88. discussion 88. X-5, X-6. [pmid: 16308883].
876 Kohl T, et al. Analysis of the stepwise clinical introduction of experimental percutaneous fetoscopic surgical techniques for upcoming minimally invasive fetal cardiac interventions. Surg Endosc. 2006;20(7):1134-1143. X-3. [pmid: 16763924].
877 Kohl T, et al. Images in cardiovascular medicine. Intraamniotic fetal echocardiography: a new fetal cardiovascular monitoring approach during human fetoscopic surgery. Circulation. 2006;114(21):e594-e596. X-5. [pmid: 17116774].
878 Kuczkowski KM. Images in Anesthesia: Ex utero intrapartum treatment (exit procedure): fetal airway management. Can J Anaesth. 2006;53(11):1117. X-6. [pmid: 17079639].
879 Kwak DW, et al. Clinical experiences of fetal ovarian cyst: diagnosis and consequence. J Korean Med Sci. 2006;21(4):690-694. X-6. [pmid: 16891814].
880 Lewi L, et al. Diagnosis and management of heterokaryotypic monochorionic twins. Am J Med Genet A. 2006;140(3):272-275. X-6. [pmid: 16411235].
881 Liao H, et al. Fetus support manipulator with flexible balloon-based stabilizer for endoscopic intrauterine surgery. Med Image Comput Comput Assist Interv Int Conf Med Image Comput Comput Assist Interv. 2006;9(Pt 1):412-419. X-3.
882 Mair R, et al. En bloc rotation of the truncus arteriosus--an option for anatomic repair of transposition of the great arteries, ventricular septal defect, and left ventricular outflow tract obstruction. J Thorac Cardiovasc Surg. 2006;131(3):740-741. X-6. [pmid: 16515936].
883 Makikallio K, et al. Fetal aortic valve stenosis and the evolution of hypoplastic left heart syndrome: patient selection for fetal intervention. Circulation. 2006;113(11):1401-1405. X-6. [pmid: 16534003].
884 Martino F, et al. Teratomas of the neck and mediastinum in children. Pediatr Surg Int. 2006;22(8):627-634. X-6. [pmid: 16838188].
885 Ong SS, et al. Laser ablation of foetal microcystic lung lesion: successful outcome and rationale for its use. Fetal Diagn Ther. 2006;21(5):471-474. X-5. [pmid: 16912498].
886 Ozcan T, et al. Use of middle cerebral artery peak systolic velocity and intrauterine transfusion for management of twin-twin transfusion and single fetal intrauterine demise. J Matern Fetal Neonatal Med. 2006;19(12):807-809. X-5. [pmid: 17190694].
887 Paladini D, et al. Diagnosis, characterization and outcome of congenitally corrected transposition of the great arteries in the fetus: a multicenter series of 30 cases. Ultrasound Obstet Gynecol. 2006;27(3):281-285. X-6. [pmid: 16485324].
888 Phaloprakarn C, Pott Bartsch EM, Harrison MR. Residual congenital cystic adenomatoid malformation and thoracic scar deformation after fetal surgery: a case report. J Pediatr Surg. 2006;41(2):e11-e14. X-5. [pmid: 16481230].
889 Pitkanen OM, et al. Borderline left ventricles in prenatally diagnosed atrioventricular septal defect or double outlet right ventricle: echocardiographic predictors of biventricular repair. Am Heart J. 2006;152(1):163e1-163e7. X-6. [pmid: 16824850].
890 Portmann-Lanz CB, et al. Placental mesenchymal stem cells as potential autologous graft for pre- and perinatal neuroregeneration. Am J Obstet Gynecol. 2006;194(3):664-673. X-1. [pmid: 16522395].
891 Poulose T, Fox R, Booth A. Unrecognised 180 degree torsion of a pregnant uterus. J Obstet Gynaecol. 2006;26(1):70-71. X-6. [pmid: 16390718].
892 Qureshi SA. Catheterization in neonates with pulmonary atresia with intact ventricular septum. Catheter Cardiovasc Interv. 2006;67(6):924-931. X-6. [pmid: 16649237].
893 Rashid N, et al. Effects of prostacyclin and milrinone on pulmonary hemodynamics in newborn lambs with persistent pulmonary hypertension induced by ductal ligation. Pediatr Res. 2006;60(5):624-629. X-3, X-6. [pmid: 16988189].
894 Ronderos-Dumit D, et al. Endoscopic release of limb constriction rings in utero. Fetal Diagn Ther. 2006;21(3):255-258. X-5. [pmid: 16601333].
895 Rosenberg E, Sheiner E, Holcberg G. Neurofibromatosis type 1 and masses of the appendix: a case report. J Reprod Med. 2006;51(7):578-580. X-5. [pmid: 16913550].
896 Scarlett MD, Tha MW. Russell-Silver syndrome: anaesthetic implications and management. West Indian Med J. 2006;55(2):127-129. X-5, X-6. [pmid: 16921710].
897 Singh AS, et al. Evaluation of human fetal bone implants in SCID mice as a model of prostate cancer bone metastasis. Oncol Rep. 2006;15(3):519-524. X-3. [pmid: 16465406].
898 Sy ED, et al. Spontaneous rupture of fetal sacrococcygeal teratoma. Fetal Diagn Ther. 2006;21(5):424-427. X-5. [pmid: 16912491].
899 Tjoa ML, et al. Circulating cell-free fetal messenger RNA levels after fetoscopic interventions of complicated pregnancies. Am J Obstet Gynecol. 2006;195(1):230-235. X-6. [pmid: 16626602].
900 Truitt AK, et al. Perinatal management of congenital cystic lung lesions in the age of minimally invasive surgery. J Pediatr Surg. 2006;41(5):893-896. X-6. [pmid: 16677877].
901 Viggiano MB, et al. Prenatal catheter placement for fetal cystic adenomatoid pulmonary malformation: a case report. Fetal Diagn Ther. 2006;21(2):194-197. X-5. [pmid: 16491002].
902 Williams C. Dilemmas in fetal medicine: premature application of technology or responding to women’s choice. Sociol Health Illn. 2006;28(1):1-20. X-1. [pmid: 16509940].
903 Woodard TD, Yong S, Hotaling AJ. The Ex Utero Intrapartum Treatment (EXIT) procedure used for airway control in a newborn with cervical fetus in fetu: a rare case. Int J Pediatr Otorhinolaryngol. 2006;70(11):1989-1994. X-5. [pmid: 16938354].
904 Yamaguchi Y, et al. Spontaneous rupture of sacrococcygeal teratoma associated with acute fetal anemia. Ultrasound Obstet Gynecol. 2006;28(5):720-722. X-5. [pmid: 16958151].
905 York DG, Wolfe H, von Allmen D. Fetal abdomino-perineal lymphangioma: differential diagnosis and management. Prenat Diagn. 2006;26(8):692-695. X-5. [pmid: 16764011].
906 Ziaei S, et al. Effect of bacterial vaginosis on premature rupture of membranes and related complications in pregnant women with a gestational age of 37–42 weeks. Gynecol Obstet Invest. 2006;61(3):135-138. X-6. [pmid: 16330881].
907 Akinturk H, et al. Hybrid transcatheter-surgical palliation: basis for univentricular or biventricular repair: the Giessen experience. Pediatr Cardiol. 2007;28(2):79-87. X-6. [pmid: 17487538].
908 Anagnostopoulos PV, et al. Neonatal mitral and tricuspid valve repair for in utero papillary muscle rupture. Ann Thorac Surg. 2007;83(4):1458-1462. X-6. [pmid: 17383357].
909 Aslanabadi S, et al. A neonate with cleft palate and a fetal mass in the oral cavity: a rare case of an oral fetus-in-fetu. Int J Pediatr Otorhinolaryngol. 2007;71(10):1617-1622. X-5, X-6. [pmid: 17628706].
910 Baschat AA, Harman CR. Acute intrapartum twin-to-twin transfusion following successful fetoscopic laser ablation. Am J Perinatol. 2007;24(4):203-205. X-5. [pmid: 17372861].
911 Bataille D, et al. In utero urinary bladder rupture: a case report. Acta Chir Belg. 2007;107(4):429-431. X-5, X-6. [pmid: 17966540].
912 Boucherat O, et al. Surfactant maturation is not delayed in human fetuses with diaphragmatic hernia. PLoS Med. 2007;4(7):e237. X-6. [pmid: 17676984].
913 Chang YL, et al. Transient chorioamniotic membrane separation after fetoscope guide laser therapy for twin-twin transfusion syndrome: a case report. Fetal Diagn Ther. 2007;22(3):180-182. X-5. [pmid: 17228154].
914 Chow PC, et al. Management and outcome of antenatally diagnosed congenital cystic adenomatoid malformation of the lung. Hong Kong Med J. 2007;13(1):31-39. X-6. [pmid: 17277390].
915 Ciardelli V, et al. Endoscopic fetal surgery: in vitro thermic effect of electrosurgical units. Prenat Diagn. 2007;27(2):170-173. X-3, X-5. [pmid: 17238216].
916 Delsing B, et al. Risk of persistent pulmonary hypertension of the neonate in twin-to-twin transfusion syndrome. Neonatology. 2007;92(2):134-138. X-6. [pmid: 17396038].
917 Farrell JA. Fetal treatment center: history, infrastructure, and nursing perspective. J Perinat Neonatal Nurs. 2007;21(1):11-19. quiz 20–21. X-1. [pmid: 17301662].
918 Finamore PS, et al. Mirror syndrome associated with sacrococcygeal teratoma: a case report. J Reprod Med. 2007;52(3):225-227. X-5. [pmid: 17465292].
919 George RB, et al. Case series: Combined spinal epidural anesthesia for Cesarean delivery and ex utero intrapartum treatment procedure. Can J Anaesth. 2007;54(3):218-222. X-6. [pmid: 17331934].
920 Glatz JA, et al. Hypoplastic left heart syndrome with atrial level restriction in the era of prenatal diagnosis. Ann Thorac Surg. 2007;84(5):1633-1638. X-6. [pmid: 17954074].
921 Harmath A, et al. Congenital lung malformations in the second trimester: prenatal ultrasound diagnosis and pathologic findings. J Clin Ultrasound. 2007;35(5):250-255. X-6. [pmid: 17373682].
922 Hirayama Y, et al. Sacral parasite with histopathological features of an unequally conjoined twin. Pediatr Surg Int. 2007;23(7):715-720. X-5, X-6. [pmid: 17351782].
923 Isnard M, et al. Successful intrauterine therapy for congenital cystic adenomatoid malformation of the lung. A case report. Fetal Diagn Ther. 2007;22(5):325-329. X-5. [pmid: 17556817].
924 JP VDW, Ross MG, MJ VANG. Twin-twin transfusion syndrome modeling. Ann N Y Acad Sci. 2007;1101:215-234. X-3. [pmid: 17363441].
925 Kamphuis MM, et al. Secondary infertility as a late complication of vesico-amniotic shunt therapy. Prenat Diagn. 2007;27(4):362-364. X-5. [pmid: 17286307].
926 Kilby M, et al. PLUTO trial protocol: percutaneous shunting for lower urinary tract obstruction randomised controlled trial. BJOG. 2007;114(7):904-905. e1. 4. X-1. [pmid: 17567421].
927 Kiziltan HT, et al. Repair of aortic coarctation and aneurysm of ductus arteriosus in the presence of right-sided arch and descending aorta. J Card Surg. 2007;22(5):440-442. X-5, X-6. [pmid: 17803589].
928 Kunisaki SM, et al. Ex utero intrapartum treatment with extracorporeal membrane oxygenation for severe congenital diaphragmatic hernia. J Pediatr Surg. 2007;42(1):98-104. discussion 104–106. X-6. [pmid: 17208548].
929 Kunisaki SM, et al. Large fetal congenital cystic adenomatoid malformations: growth trends and patient survival. J Pediatr Surg. 2007;42(2):404-410. X-6. [pmid: 17270558].
930 Kunisaki SM, et al. Ex utero intrapartum treatment with placement on extracorporeal membrane oxygenation for fetal thoracic masses. J Pediatr Surg. 2007;42(2):420-425. X-6. [pmid: 17270561].
931 Lang E, et al. Ex utero intrapartum treatment (EXIT) procedure and simultaneous excision of oral teratoma. Ir Med J. 2007;100(10):632-633. X-5. [pmid: 18277735].
932 Lee H, et al. Efficacy of radiofrequency ablation for twin-reversed arterial perfusion sequence. Am J Obstet Gynecol. 2007;196(5):459e1-459e4. X-6. [pmid: 17466701].
933 Livingston JC, et al. Intrafetal radiofrequency ablation for twin reversed arterial perfusion (TRAP): a single-center experience. Am J Obstet Gynecol. 2007;197(4):399e1-399e3. X-6. [pmid: 17904976].
934 Livingston JC, et al. Mirror syndrome: a novel approach to therapy with fetal peritoneal-amniotic shunt. Obstet Gynecol. 2007;110(2 Pt 2):540-543. X-5. [pmid: 17666658].
935 Lopriore E, et al. Assessment of feto-fetal transfusion flow through placental arterio-venous anastomoses in a unique case of twin-to-twin transfusion syndrome. Placenta. 2007;28(2–3):209-211. X-5. [pmid: 16678896].
936 Majhi AK, et al. Fetus in fetu--a mystery in medicine. ScientificWorldJournal. 2007;7:252-257. X-5, X-6. [pmid: 17334616].
937 Marinoni E, et al. Intravaginal gemeprost and second-trimester pregnancy termination in the scarred uterus. Int J Gynaecol Obstet. 2007;97(1):35-39. X-6. [pmid: 17320086].
938 Matsui H, Gardiner H. Fetal intervention for cardiac disease: the cutting edge of perinatal care. Semin Fetal Neonatal Med. 2007;12(6):482-489. X-1. [pmid: 17827079].
939 Mota R, et al. Evolving indications for the EXIT procedure: the usefulness of combining ultrasound and fetal MRI. Fetal Diagn Ther. 2007;22(2):107-111. X-6. [pmid: 17135754].
940 Nezafati MH, Soltani G, Vedadian A. Video-assisted ductal closure with new modifications: minimally invasive, maximally effective, 1,300 cases. Ann Thorac Surg. 2007;84(4):1343-1348. X-6. [pmid: 17888995].
941 Oepkes D, et al. Successful ultrasound-guided laser treatment of fetal hydrops caused by pulmonary sequestration. Ultrasound Obstet Gynecol. 2007;29(4):457-459. X-5. [pmid: 17352451].
942 Okutomi T, Saito M, Kuczkowski KM. The use of potent inhalational agents for the ex-utero intrapartum treatment (exit) procedures: what concentrations. Acta Anaesthesiol Belg. 2007;58(2):97-99. X-5. [pmid: 17710896].
943 Pachydakis A, Belgaumkar PV, Patel R. Intra-partum transvaginal cranial decompression of intracranial teratoma. J Obstet Gynaecol. 2007;27(1):85-86. X-5. [pmid: 17365471].
944 Pedreira DA, et al. Validation of the ovine fetus as an experimental model for the human myelomeningocele defect. Acta Cir Bras. 2007;22(3):168-173. X-3, X-6. [pmid: 17546288].
945 Peranteau WH, et al. Effect of maternal betamethasone administration on prenatal congenital cystic adenomatoid malformation growth and fetal survival. Fetal Diagn Ther. 2007;22(5):365-371. X-1. [pmid: 17556826].
946 Peterson EC, et al. Epidural metastases from endodermal sinus tumor arising from benign sacral teratoma. Case report and review of the literature. J Neurosurg. 2007;107(4 Suppl):303-306. X-5, X-6. [pmid: 17941495].
947 Quintero R, et al. Fetal laryngoscopy and lung biopsy in a case of bilateral lethal congenital cystic adenomatoid malformation of the lung. Fetal Pediatr Pathol. 2007;26(5–6):229-234. X-5. [pmid: 18363155].
948 Rocha G, et al. Congenital cystic adenomatoid malformation of the lung—the experience of five medical centres. Rev Port Pneumol. 2007;13(4):511-523. X-5. [pmid: 17898911].
949 Rogers TN, et al. Solitary liver cysts in children: not always so simple. J Pediatr Surg. 2007;42(2):333-339. X-6. [pmid: 17270544].
950 Ruano R, et al. Percutaneous intrauterine laser ablation of the abnormal vessel in pulmonary sequestration with hydrops at 29 weeks’ gestation. J Ultrasound Med. 2007;26(9):1235-1241. X-5. [pmid: 17715320].
951 Sanchez e Oliveira Rde C, et al. Biosynthetic cellulose induces the formation of a neoduramater following pre-natal correction of meningomyelocele in fetal sheep. Acta Cir Bras. 2007;22(3):174-181. X-6. [pmid: 17546289].
952 Santiago-Munoz PC, et al. Outcomes of pregnancies with fetal gastroschisis. Obstet Gynecol. 2007;110(3):663-668. X-6. [pmid: 17766615].
953 Santolaya-Forgas J, et al. A study to determine if human umbilical cord hematopoietic stem cells can survive in baboon extra-embryonic celomic fluid: a prerequisite for determining the feasibility of in-utero stem cell xeno-transplantation via celocentesis. Fetal Diagn Ther. 2007;22(2):131-135. X-3. [pmid: 17139170].
954 Sekarski N, et al. Right ventricular outflow tract reconstruction with the bovine jugular vein graft: 5 years’ experience with 133 patients. Ann Thorac Surg. 2007;84(2):599-605. X-6. [pmid: 17643642].
955 Shimabukuro F, et al. A case of congenital high airway obstruction syndrome managed by ex utero intrapartum treatment: case report and review of the literature. Am J Perinatol. 2007;24(3):197-201. X-6. [pmid: 17372858].
956 Sierra J, et al. Right ventricular outflow tract reconstruction: what conduit to use? Homograft or Contegra. Ann Thorac Surg. 2007;84(2):606-610. discussion 610–611. X-6. [pmid: 17643643].
957 Sista AK, Filly RA. Paradoxical movement of abdominal contents: a real-time sonographic finding indicating a congenital diaphragmatic hernia. J Ultrasound Med. 2007;26(11):1617-1619. X-6. [pmid: 17957056].
958 Thoannes H, Visseaux H, Malinovsky JM. Labour analgesia and scabies. Int J Obstet Anesth. 2007;16(3):293-294. X-6. [pmid: 17459689].
959 van den Wijngaard JP, et al. Modeling severely discordant hematocrits and normal amniotic fluids after incomplete laser therapy in twin-to-twin transfusion syndrome. Placenta. 2007;28(7):611-615. X-3. [pmid: 17098282].
960 Ville Y. Twin-to-twin transfusion syndrome: time to forget the Quintero staging system. Ultrasound Obstet Gynecol. 2007;30(7):924-927. X-1. [pmid: 18044824].
961 Wataganara T, et al. Fetal neck myofibroma. J Med Assoc Thai. 2007;90(2):376-380. X-5. [pmid: 17375646].
962 Yamamoto M, et al. Intrathoracic pressure in congenital chylothorax: keystone for the rationale of thoracoamniotic shunting. Fetal Diagn Ther. 2007;22(3):169-171. X-5. [pmid: 17228151].
963 Yoshinaga T, et al. Neural stem cell transplantation in a model of fetal alcohol effects. J Neural Transm Suppl. 2007(72):331-337. X-3. [pmid: 17982911].
964 Zambelli H, et al. Successful developmental outcome in intrauterine myelomeningocele repair. Childs Nerv Syst. 2007;23(1):123-126. X-5. [pmid: 16944176].
965 Zambelli H, et al. Assessment of neurosurgical outcome in children prenatally diagnosed with myelomeningocele and development of a protocol for fetal surgery to prevent hydrocephalus. Childs Nerv Syst. 2007;23(4):421-425. X-6. [pmid: 17226038].
966 Akcurin G, et al. Giant aneurysm of the ductus arteriosus. Anadolu Kardiyol Derg. 2008;8(4):E28-E29. X-1. [pmid: 18676296].
967 Al-Anazi A, Al-Mejhim F, Al-Qahtani N. In uteroventriculo-amniotic shunt for hydrocephalus. Childs Nerv Syst. 2008;24(2):193-195. X-4, X-5. [pmid: 17876591].
968 Arbell D, et al. Prepartum sonographic demonstration of ‘to-and-fro’ motion in fetal intestinal obstruction: a novel sign for immediate postnatal surgery. Ultrasound Obstet Gynecol. 2008;32(1):112-114. X-5. [pmid: 18435527].
969 Baldassarre ME, et al. A case of fetal midgut volvulus and jejunal atresia: nutritional support and maintenance of mucosal function and integrity. Immunopharmacol Immunotoxicol. 2008;30(3):601-608. X-5. [pmid: 18668397].
970 Butera G, et al. Percutaneous treatment of ductal origin of the distal pulmonary artery in low-weight newborns. J Invasive Cardiol. 2008;20(7):354-356. X-6. [pmid: 18599894].
971 Cabral AC, et al. Cardiofemoral index as an ultrasound marker of fetal anemia in isoimmunized pregnancy. Int J Gynaecol Obstet. 2008;100(1):60-64. X-6. [pmid: 17900583].
972 Calvaruso D, et al. Images in cardiovascular medicine: right ventricular outflow tract reconstruction with contegra bovine valved conduit. Circulation. 2008;118(15):e519-e520. X-5. [pmid: 18838569].
973 Chakraborty A, et al. Toward reducing shunt placement rates in patients with myelomeningocele. J Neurosurg Pediatrics. 2008;1(5):361-365. X-6.
974 Chang LC, Kuczkowski KM. The ex utero intrapartum treatment procedure: anesthetic considerations. Arch Gynecol Obstet. 2008;277(1):83-85. X-5. [pmid: 17619892].
975 Clifton MS, et al. Fetoscopic transuterine release of posterior urethral valves: a new technique. Fetal Diagn Ther. 2008;23(2):89-94. X-5. [pmid: 18033963].
976 Croti UA, et al. The use of decellularized homograft monocuspid in the treatment of truncus arterious by Barbero Marcial technique. Rev Bras Cir Cardiovasc. 2008;23(2):290-291. X-5. [pmid: 18820798].
977 Davis J, Fernando JJ. Successful management of prenatal hydrops fetalis in a mother with HIV. Int J STD AIDS. 2008;19(4):281-282. X-5, X-6. [pmid: 18482951].
978 Delahaye S, et al. Prenatal diagnosis of dumbbell neuroblastoma. Ultrasound Obstet Gynecol. 2008;31(1):92-95. X-6. [pmid: 18058843].
979 Encinas Hernandez JL, et al. Brain malformations in the sheep model of myelomeningocele are similar to those found in human disease: preliminary report. Pediatr Surg Int. 2008;24(12):1335-1340. X-3, X-4. [pmid: 18989683].
980 Fadler KM, Askin DF. Sacrococcygeal teratoma in the newborn: a case study of prenatal management and clinical intervention. Neonatal Netw. 2008;27(3):185-191. X-5. [pmid: 18557266].
981 Galantowicz M, et al. Hybrid approach for hypoplastic left heart syndrome: intermediate results after the learning curve. Ann Thorac Surg. 2008;85(6):2063-2070. discussion 2070–2071. X-6. [pmid: 18498821].
982 Gardiner HM. In-utero intervention for severe congenital heart disease. Best Pract Res Clin Obstet Gynaecol. 2008;22(1):49-61. X-1, X-5. [pmid: 17697798].
983 Gillham J, et al. An unusual complication of in utero pleuro-amniotic shunting for fetal pleural effusion. Eur J Obstet Gynecol Reprod Biol. 2008;140(2):285-286. X-5. [pmid: 18353526].
984 Grgic O, Radakovic B, Barisic D. Hyperreactio luteinalis could be a risk factor for development of HELLP syndrome: case report. Fertil Steril. 2008;90(5):2008 e13-e16. X-5. [pmid: 18829007].
985 Guillot PV, et al. Transplantation of human fetal mesenchymal stem cells improves glomerulopathy in a collagen type I alpha 2-deficient mouse. J Pathol. 2008;214(5):627-636. X-3. [pmid: 18266309].
986 Henaine R, et al. Fate of the truncal valve in truncus arteriosus. Ann Thorac Surg. 2008;85(1):172-178. X-6. [pmid: 18154803].
987 Hickey EJ, et al. Jugular venous valved conduit (Contegra) matches allograft performance in infant truncus arteriosus repair. Eur J Cardiothorac Surg. 2008;33(5):890-898. X-6. [pmid: 18313324].
988 Holcroft CJ, et al. Large fetal sacrococcygeal teratomas: could early delivery improve outcome. Fetal Diagn Ther. 2008;24(1):55-60. X-6. [pmid: 18504383].
989 Ibele A, Flake A, Shaaban A. Survival of a profoundly hydropic fetus with a sacrococcygeal teratoma delivered at 27 weeks of gestation for maternal mirror syndrome. J Pediatr Surg. 2008;43(8):e17-e20. X-5. [pmid: 18675620].
990 Ishii K, et al. Anemia in a recipient twin unrelated to twin anemia-polycythemia sequence subsequent to sequential selective laser photocoagulation of communicating vessels for twin-twin transfusion syndrome. Prenat Diagn. 2008;28(3):262-263. X-5. [pmid: 18264950].
991 Kim A, et al. A rare case of posterior urethral valve and pleural effusion in Down syndrome with successful intrauterine shunt. Fetal Diagn Ther. 2008;24(4):372-375. X-4, X-5. [pmid: 18936544].
992 Kuwashima S, et al. MR imaging appearance of laryngeal atresia (congenital high airway obstruction syndrome): unique course in a fetus. Pediatr Radiol. 2008;38(3):344-347. X-5, X-6. [pmid: 18071686].
993 Lewi L, et al. The outcome of monochorionic diamniotic twin gestations in the era of invasive fetal therapy: a prospective cohort study. Am J Obstet Gynecol. 2008;199(5):514e1-514e8. X-6. [pmid: 18533114].
994 Lewi L, et al. The role of ultrasound examination in the first trimester and at 16 weeks’ gestation to predict fetal complications in monochorionic diamniotic twin pregnancies. Am J Obstet Gynecol. 2008;199(5):493e1-493e7. X-6. [pmid: 18539256].
995 Liao H, et al. Fetus-supporting flexible manipulator with balloon-type stabilizer for endoscopic intrauterine surgery. Int J Med Robot. 2008;4(3):214-223. X-5. [pmid: 18680139].
996 Lopriore E, et al. Fetoscopic laser treatment of twin-to-twin transfusion syndrome followed by severe twin anemia-polycythemia sequence with spontaneous resolution. Am J Obstet Gynecol. 2008;198(2):e4-e7. X-5. [pmid: 18226611].
997 Matsubara M, et al. Resolution of mirror syndrome after successful fetoscopic laser photocoagulation of communicating placental vessels in severe twin-twin transfusion syndrome. Prenat Diagn. 2008;28(12):1167-1168. X-4. [pmid: 18925575].
998 Morikawa M, et al. Ileal atresia after fetoscopic laser photocoagulation for twin-to-twin transfusion syndrome—a case report. Prenat Diagn. 2008;28(11):1072-1074. X-4. [pmid: 18925560].
999 Morota N, Ihara S. Postnatal ascent of the cerebellar tonsils in Chiari malformation Type II following surgical repair of myelomeningocele. J Neurosurg Pediatrics. 2008;2(3):188-193. X-6.
1000 Nakata M, et al. Fetoscopic laser photocoagulation of placental communicating vessels for twin-reversed arterial perfusion sequence. J Obstet Gynaecol Res. 2008;34(4 Pt 2):649-652. X-5. [pmid: 18840173].
1001 Nejat F, Kazmi SS, Ardakani SB. Congenital brain tumors in a series of seven patients. Pediatr Neurosurg. 2008;44(1):1-8. X-6. [pmid: 18097184].
1002 Okada T, et al. Management and outcome in prenatally diagnosed sacrococcygeal teratomas. Pediatr Int. 2008;50(4):576-580. X-5. [pmid: 18937757].
1003 Okawa T, et al. Repeated paracentesis in a fetus with meconium peritonitis with massive ascites: a case report. Fetal Diagn Ther. 2008;24(2):99-102. X-5. [pmid: 18648207].
1004 Papadias A, et al. Comparison of prenatal and postnatal MRI findings in the evaluation of intrauterine CNS anomalies requiring postnatal neurosurgical treatment. Childs Nerv Syst. 2008;24(2):185-192. X-5. [pmid: 17710413].
1005 Park CS, et al. Lecompte operation: is it still a viable option for truncus arteriosus. J Thorac Cardiovasc Surg. 2008;136(5):1384-1386. 1386e1. 1386e2. X-6. [pmid: 19026841].
1006 Park JS, et al. Intrauterine midgut volvulus without malrotation: diagnosis from the ‘coffee bean sign’. World J Gastroenterol. 2008;14(9):1456-1458. X-5, X-6. [pmid: 18322966].
1007 Pedreira DA, et al. Gasless fetoscopy: a new approach to endoscopic closure of a lumbar skin defect in fetal sheep. Fetal Diagn Ther. 2008;23(4):293-298. X-3. [pmid: 18417995].
1008 Phi JH, et al. Congenital subependymal giant cell astrocytoma: clinical considerations and expression of radial glial cell markers in giant cells. Childs Nerv Syst. 2008;24(12):1499-1503. X-4, X-5. [pmid: 18629509].
1009 Pilla CB, et al. Hybrid management for hypoplastic left heart syndrome : an experience from Brazil. Pediatr Cardiol. 2008;29(3):498-506. X-6. [pmid: 18080154].
1010 Quintero RA, et al. In utero fetal oximetry via visible light spectroscopy in twin-twin transfusion syndrome. Am J Obstet Gynecol. 2008;199(6):639e1-639e4. X-5. [pmid: 18667174].
1011 Ramanah R, et al. The uterosacral complex: ligament or neurovascular pathway? Anatomical and histological study of fetuses and adults. Int Urogynecol J Pelvic Floor Dysfunct. 2008;19(11):1565-1570. X-5. [pmid: 18668191].
1012 Ramos E, Marlin AE, Gaskill SJ. Congenital dermoid tumor in a child at initial myelomeningocele closure: an etiological discussion. J Neurosurg Pediatr. 2008;2(6):414-415. X-4. [pmid: 19035687].
1013 Rizkalla HF, et al. Pathological findings associated with the presence of a mirena intrauterine system at hysterectomy. Int J Gynecol Pathol. 2008;27(1):74-78. X-6. [pmid: 18156979].
1014 Robinson MB, Crombleholme TM, Kurth CD. Maternal pulmonary edema during fetoscopic surgery. Anesth Analg. 2008;107(6):1978-1980. X-5. [pmid: 19020148].
1015 Ruano R, et al. To shunt or not to shunt a pulmonary adenomatoid cystic malformation after 33 weeks of gestation: a case report. Sao Paulo Med J. 2008;126(4):239-241. X-4. [pmid: 18853037].
1016 Sago H, et al. Endoscopic fetal urethrotomy for anterior urethral valves: a preliminary report. Fetal Diagn Ther. 2008;24(2):92-95. X-5. [pmid: 18648205].
1017 Salomon LJ, et al. Emergency cerclage in cases of twin-to-twin transfusion syndrome with a short cervix at the time of surgery and relationship to perinatal outcome. Prenat Diagn. 2008;28(13):1256-1261. X-5. [pmid: 19039797].
1018 Santo S, et al. Prenatal ultrasonographic diagnosis of abdominal cystic lymphangioma: a case report. J Matern Fetal Neonatal Med. 2008;21(8):565-566. X-5. [pmid: 18609355].
1019 Saygili-Yilmaz ES, et al. Prenatal diagnosis of type I sacrococcygeal teratoma and its management. Clin Exp Obstet Gynecol. 2008;35(2):153-155. X-5. [pmid: 18581776].
1020 Shinebourne EA, Rigby ML, Carvalho JS. Pulmonary atresia with intact ventricular septum: from fetus to adult: congenital heart disease. Heart. 2008;94(10):1350-1357. X-6. [pmid: 18801793].
1021 Sival DA, et al. Spinal hemorrhages are associated with early neonatal motor function loss in human spina bifida aperta. Early Hum Dev. 2008;84(7):423-431. X-6. [pmid: 18180116].
1022 Sueters M, et al. Fetal cardiac output in monochorionic twins. Ultrasound Obstet Gynecol. 2008;32(6):807-812. X-5. [pmid: 18956438].
1023 Tofigh AM, et al. Fetus in fetu: report of a case and literature review. Int J Surg. 2008;6(6):e94-e96. X-4. [pmid: 17604707].
1024 Turgut M. Pediatric neurosurgical techniques in the 15th century. J Clin Neurosci. 2008;15(10):1085-1090. X-1. [pmid: 18703338].
1025 Turgut M. Surgical instruments utilized in foetal hydrocephalus to prevent the mother’s death at the time of Serefeddin Sabuncuoglu 1385–1468 AD). Childs Nerv Syst. 2008;24(7):783. X-4, X-5. [pmid: 18157538].
1026 van Gemert MJ, et al. Simulated sequential laser therapy of twin-twin transfusion syndrome. Placenta. 2008;29(7):609-613. X-3. [pmid: 18490053].
1027 van Gemert MJ, et al. Arterio-venous flow between monochorionic twins determined during intra-uterine transfusion. Phys Med Biol. 2008;53(7):N109-N117. X-6. [pmid: 18354242].
1028 Vladareanu R. Progress in obstetrics or the road to the promised land, J Med Life. 2008;1(1):55-59. X-1, X-4, X-5.
1029 Vogler SA, et al. Closed gastroschisis: total parenteral nutrition-free survival with aggressive attempts at bowel preservation and intestinal adaptation. J Pediatr Surg. 2008;43(6):1006-1010. X-6. [pmid: 18558174].
1030 Wang Y, et al. Management of nuchal cord with multiple loops. Obstet Gynecol. 2008;112(2 Pt 2):460-461. X-5. [pmid: 18669764].
1031 Williams H. Gender, head size and disease: a hypothesis related to posterior fossa growth. Med Hypotheses. 2008;70(6):1108-1111. X-1. [pmid: 18179874].
1032 Wilson RD, Chitty LS. Anomalies of the fetal thorax and abdomen: diagnosis, management and outcome. Prenat Diagn. 2008;28(7):567. X-1. [pmid: 18634118].
1033 Woerner A, et al. Neonatological and pulmonological management of bilateral pulmonary sequestration in a neonate. World J Pediatr. 2008;4(4):301-304. X-4. [pmid: 19104895].
1034 Yamashita H, et al. Miniature bending manipulator for fetoscopic intrauterine laser therapy to treat twin-to-twin transfusion syndrome. Surg Endosc. 2008;22(2):430-435. X-3. [pmid: 17661138].
1035 Zampieri N, et al. Foetal and neonatal ovarian cysts: a 5-year experience. Arch Gynecol Obstet. 2008;277(4):303-306. X-6. [pmid: 17952447].
1036 Zani A, et al. Not all symptoms disappear after vascular ring division: a pathophysiological interpretation. Pediatr Cardiol. 2008;29(3):676-678. X-5, X-6. [pmid: 17851633].
1037 Zhou C, et al. Changes in atrial natriuretic peptide levels during cardiac bypass in the fetal goat. Artif Organs. 2008;32(12):956-961. X-3, X-4, X-5. [pmid: 19133024].
1038 Abi-Nader K, et al. Successful outcome after prenatal treatment of a cardiac diverticulum with massive pericardial effusion. Fetal Diagn Ther. 2009;25(1):148-152. X-4, X-5. [pmid: 19287174].
1039 Alkazaleh F, Saleem M, Badran E. Intrathoracic displacement of pleuroamniotic shunt after successful in utero treatment of fetal hydrops secondary to hydrothorax. Case report and review of the literature. Fetal Diagn Ther. 2009;25(1):40-43. X-4, X-5. [pmid: 19176969].
1040 Allegaert K, et al. Cefazolin pharmacokinetics in maternal plasma and amniotic fluid during pregnancy. Am J Obstet Gynecol. 2009;200(2):170e1-170e7. X-5. [pmid: 19006783].
1041 Alsaid B, et al. Coexistence of adrenergic and cholinergic nerves in the inferior hypogastric plexus anatomical and immunohistochemical study with 3D reconstruction in human male fetus. J Anat. 2009;214(5):645-654. X-5. [pmid: 19438760].
1042 Arlikar JD, et al. Fetus in fetu: two case reports and review of literature. Pediatr Surg Int. 2009;25(3):289-292. X-5. [pmid: 19184054].
1043 Ballard HO, et al. An embolic complication in a donor twin with severe twin-twin transfusion syndrome after fetoscopic intervention. J Perinatol. 2009;29(3):250-251. X-4. [pmid: 19240730].
1044 Benirschke K. The monozygotic twinning process, the twin-twin transfusion syndrome and acardiac twins. Placenta. 2009;30(11):923-928. X-1, X-3, X-4. [pmid: 19748667].
1045 Butwick A, Aleshi P, Yamout I. Obstetric hemorrhage during an EXIT procedure for severe fetal airway obstruction. Can J Anaesth. 2009;56(6):437-442. X-4, X-5. [pmid: 19396506].
1046 Cavoretto P, et al. Early diagnosis, follow-up, and prenatal treatment of a case of TRAP sequence occurring in a dichorionic triamniotic triplet pregnancy. J Clin Ultrasound. 2009;37(6):350-353. X-4, X-5. [pmid: 19444901].
1047 Chelli Bouaziz M, et al. Extralobar pulmonary sequestration revealed by prenatal hydrothorax. Tunis Med. 2009;87(10):712-715. X-4. [pmid: 20187365].
1048 Clyman R, et al. The role of patent ductus arteriosus ligation in bronchopulmonary dysplasia: reexamining a randomized controlled trial. J Pediatr. 2009;154(6):873-876. X-5. [pmid: 19324366].
1049 Danzer E, et al. In utero meconium passage in fetuses and newborns with myelomeningocele. J Neurosurg Pediatr. 2009;3(2):141-146. X-5. [pmid: 19278315].
1050 De Lia JE, et al. Placental laser surgery for severe previable feto-fetal transfusion syndrome in triplet gestation. Am J Perinatol. 2009;26(8):559-564. X-5. [pmid: 19391083].
1051 Deprest JA, et al. Antenatal prediction of lung volume and in-utero treatment by fetal endoscopic tracheal occlusion in severe isolated congenital diaphragmatic hernia. Semin Fetal Neonatal Med. 2009;14(1):8-13. X-1, X-3, X-4. [pmid: 18845492].
1052 Deprest JA, et al. Current controversies in prenatal diagnosis 4: Should fetal surgery be done in all cases of severe diaphragmatic hernia. Prenat Diagn. 2009;29(1):15-19. X-1, X-4. [pmid: 19125386].
1053 Draper H, et al. Long-term functional results following resection of neonatal sacrococcygeal teratoma. Pediatr Surg Int. 2009;25(3):243-246. X-5. [pmid: 19189110].
1054 Ellwood D. As good as it gets in fetal therapy?. Aust N Z J Obstet Gynaecol. 2009;49(1):1. X-1. [pmid: 19281570].
1055 Fenghua W, et al. Does intervention in utero preserve the obstructed kidneys of fetal lambs? A histological, cytological, and molecular study. Pediatr Res. 2009;66(2):145-148. X-3, X-5. [pmid: 19390481].
1056 Fichera A, et al. Severe brain damage from twin-twin transfusion syndrome treated with serial amnioreductions after 26 weeks: a case to reconsider the gestational age limits of laser therapy. Fetal Diagn Ther. 2009;25(2):203-205. X-4. [pmid: 19372697].
1057 Filipchuck D, Avdimiretz L. The ex utero intrapartum treatment (EXIT) procedure for fetal head and neck masses. AORN J. 2009;90(5):661-672. quiz 673–676. X-4. [pmid: 19953730].
1058 Fox CE, et al. Reversed twin-to-twin transfusion syndrome following successful laser therapy. Fetal Diagn Ther. 2009;26(2):115-118. X-4. [pmid: 19752513].
1059 Fox CE, et al. Maternal serum markers of placental damage in uncomplicated dichorionic and monochorionic pregnancies in comparison with monochorionic pregnancies complicated by severe twin-to-twin transfusion syndrome and the response to fetoscopic laser ablation. Eur J Obstet Gynecol Reprod Biol. 2009;144(2):124-129. X-5. [pmid: 19362410].
1060 Guida M, et al. Spinal dysraphism in an early missed abortion: embryofetoscopic diagnosis. J Minim Invasive Gynecol. 2009;16(6):768-771. X-4, X-5. [pmid: 19896607].
1061 Hache JJ, Emery SP, Vallejo MC. Bilateral fetal hydrothorax requiring intrauterine fetal thoracoamniotic shunts: anesthetic considerations and management. ScientificWorldJournal. 2009;9:435-440. X-4, X-5. [pmid: 19526182].
1062 Harada K, et al. ICG fluorescence endoscope for visualization of the placental vascular network. Minim Invasive Ther Allied Technol. 2009;18(1):1-5. X-1, X-3, X-4. [pmid: 19123103].
1063 Hartnick CJ, et al. Case records of the Massachusetts General Hospital Case 7-2009. A pregnant woman with a large mass in the fetal oral cavity. N Engl J Med. 2009;360(9):913-921. X-4, X-5. [pmid: 19246364].
1064 Henry PY, et al. Extrauterine Intrapartum Treatment (EXIT) in bilateral primary fetal hydrothorax. Indian J Pediatr. 2009;76(1):99-101. X-5. [pmid: 19391012].
1065 Herway C, et al. Fetal intraperitoneal transfusion for iatrogenic twin anemia-polycythemia sequence after laser therapy. Ultrasound Obstet Gynecol. 2009;33(5):592-594. X-4. [pmid: 19402103].
1066 Hidaka N, et al. Prenatal diagnosis of trisomy 16 mosaicism manifested as pulmonary artery stenosis. J Clin Ultrasound. 2009;37(2):107-111. X-4, X-5. [pmid: 18506747].
1067 Jancelewicz T, Harrison MR. A history of fetal surgery. Clin Perinatol. 2009;36(2):227-236. vii. X-1, X-3, X-4, X-5. [pmid: 19559317].
1068 Jelin E, Jelin AC, Lee H. Sacrococcygeal teratoma with spinal canal invasion prenatally diagnosed. J Pediatr Surg. 2009;44(4):E9-E11. X-1, X-4. [pmid: 19361623].
1069 Jesudian V, Ravikumar R, Kumar RS. Isolation of the left subclavian artery-origin from the left pulmonary artery by way of ductus arteriosus: multidetector row computed tomographic angiographic imaging. Pediatr Cardiol. 2009;30(4):549-550. X-4, X-5. [pmid: 19280246].
1070 Jimenez JS, et al. Conservative management of retained trophoblastic tissue and placental polyp with diagnostic ambulatory hysteroscopy. Eur J Obstet Gynecol Reprod Biol. 2009;145(1):89-92. X-4, X-5. [pmid: 19409686].
1071 Joshi M, et al. Foetus in fetu with common bile duct injury: a case report and review of literature. ANZ J Surg. 2009;79(9):651-652. X-4, X-5. [pmid: 19895523].
1072 Kalu E, Richardson R. Retained foetal bones: an intrauterine cause of chronic pelvic pain. Arch Gynecol Obstet. 2009;279(2):233-234. X-4, X-5. [pmid: 18506460].
1073 Kohl T, et al. Is there a therapeutic role for fetoscopic surgery in the prenatal treatment of gastroschisis? A feasibility study in sheep. Surg Endosc. 2009;23(7):1499-1505. X-3, X-4, X-5. [pmid: 19263117].
1074 Kohl T, et al. Percutaneous fetoscopic laser decompression of congenital high airway obstruction syndrome (CHAOS) from laryngeal atresia via a single trocar—current technical constraints and potential solutions for future interventions. Fetal Diagn Ther. 2009;25(1):67-71. X-4, X-5. [pmid: 19202341].
1075 Koszutski T, et al. Babies with myelomeningocele in Poland: parents’ attitudes on fetal surgery versus termination of pregnancy. Childs Nerv Syst. 2009;25(2):207-210. X-1, X-4. [pmid: 18560842].
1076 Kuehnl A, et al. Floating caval thrombus arising from the ovarian vein. Ann Vasc Surg. 2009;23(5):688e7-688e9. X-4, X-5. [pmid: 19747614].
1077 Lambretti S. Fetal surgery. Radiol Technol. 2009;81(2):194-198. X-1. [pmid: 19901361].
1078 Lee H. Fetal surgery is a multidisciplinary field that relies on the participation and expertise of a variety of clinicians and support staff. Preface. Clin Perinatol. 2009;36(2):xv-xvi. X-1, X-2, X-3, X-4.
1079 Leung TY, et al. Urgent cesarean delivery for fetal bradycardia. Obstet Gynecol. 2009;114(5):1023-1028. X-5. [pmid: 20168102].
1080 Liao H, et al. Fast image mapping of endoscopic image mosaics with three-dimensional ultrasound image for intrauterine fetal surgery. Minim Invasive Ther Allied Technol. 2009;18(6):332-340. X-1, X-3, X-4. [pmid: 19929295].
1081 Lopriore E, et al. Residual anastomoses in twin-to-twin transfusion syndrome treated with selective fetoscopic laser surgery: localization, size, and consequences. Am J Obstet Gynecol. 2009;201(1):66e1-66e4. X-5. [pmid: 19306965].
1082 Lopriore E, et al. Quantification of feto-fetal transfusion rate through a single placental arterio-venous anastomosis in a monochorionic twin pregnancy. Placenta. 2009;30(3):223-225. X-4. [pmid: 19108886].
1083 Mah VK, et al. Absolute vs relative improvements in congenital diaphragmatic hernia survival: what happened to “hidden mortality.”. J Pediatr Surg. 2009;44(5):877-882. X-5. [pmid: 19433161].
1084 McCann SM, Emery SP, Vallejo MC. Anesthetic management of a parturient with fetal sacrococcygeal teratoma and mirror syndrome complicated by elevated hCG and subsequent hyperthyroidism. J Clin Anesth. 2009;21(7):521-524. X-4. [pmid: 20006261].
1085 Moise KJ Jr, et al. Fetal intervention: providing reasonable access to quality care. Obstet Gynecol. 2009;113(2 Pt 1):408-410. X-1. [pmid: 19155914].
1086 Morris LM, Lim FY, Crombleholme TM. Ex utero intrapartum treatment procedure: a peripartum management strategy in particularly challenging cases. J Pediatr. 2009;154(1):126-131 e3. X-5. [pmid: 19187733].
1087 Morris LM, et al. Severe micrognathia: indications for EXIT-to-Airway. Fetal Diagn Ther. 2009;26(3):162-166. X-5. [pmid: 19776546].
1088 Mychaliska GB, et al. Giant pulmonary sequestration: the rare case requiring the EXIT procedure with resection and ECMO. Fetal Diagn Ther. 2009;25(1):163-166. X-1, X-3, X-4, X-5. [pmid: 19293587].
1089 Nagao Y, et al. Improved efficacy and safety of in utero cell transplantation in sheep using an ultrasound-guided method. Cloning Stem Cells. 2009;11(2):281-285. X-3, X-4, X-5. [pmid: 19522675].
1090 Odibo AO, et al. Selective laser photocoagulation versus serial amniodrainage for the treatment of twin-twin transfusion syndrome: a cost-effectiveness analysis. J Perinatol. 2009;29(8):543-547. X-5. [pmid: 19339984].
1091 O’Donoghue K, et al. Transfusional fetal complications after single intrauterine death in monochorionic multiple pregnancy are reduced but not prevented by vascular occlusion. BJOG. 2009;116(6):804-812. X-5. [pmid: 19432569].
1092 Parlakgumus HA, Tarim E, Ezer SS. Antenatal diagnosis of sacrococcygeal teratoma—two different case reports. Ginekol Pol. 2009;80(6):445-448. X-4, X-5, NO FETAL INTERVENTION. [pmid: 19642602].
1093 Puvanachandra N, Clifford L, Gaston H. Retinopathy of prematurity in twin-twin transfusion syndrome. J Pediatr Ophthalmol Strabismus. 2009;46(4):226-227. X-4. [pmid: 19645402].
1094 Ruano R, Duarte S, Zugaib M. Percutaneous laser ablation of sacrococcygeal teratoma in a hydropic fetus with severe heart failure—too late for a surgical procedure. Fetal Diagn Ther. 2009;25(1):26-30. X-4. [pmid: 19129708].
1095 Ruano R, et al. Four-dimensional ultrasonographic imaging of fetal lower urinary tract obstruction and guidance of percutaneous cystoscopy. Ultrasound Obstet Gynecol. 2009;33(2):250-252. X-4, X-5. [pmid: 19173237].
1096 Said S, et al. Prenatal diagnosis of massive fetal tongue teratoma followed by successful, ex-utero intra-partum treatment. J Obstet Gynaecol. 2009;29(1):55-57. X-4, X-5. [pmid: 19280499].
1097 Scott CK, et al. Ductal arteriosus aneurysm, right aortic arch, and isolated left subclavian artery in a neonate. Congenit Heart Dis. 2009;4(3):187-189. X-4, X-5. [pmid: 19489948].
1098 Seki T, et al. Blood flow measurement system for fetoscopic laser photocoagulation of chorionic plate anastomosing vessels (FLPC). Minim Invasive Ther Allied Technol. 2009;18(6):350-355. X-3. [pmid: 19929297].
1099 Simpson JM. Fetal cardiac interventions: worth it. Heart. 2009;95(20):1653-1655. X-1. [pmid: 19443474].
1100 Slodki M, et al. Fetal echocardiography before and after prenatal aspiration of a fetal ovarian cyst. Ginekol Pol. 2009;80(8):629-631. X-4, X-5. [pmid: 19824464].
1101 Slodki M, et al. Hydrothorax treated in utero and monitored by fetal echocardiography. Ginekol Pol. 2009;80(5):386-389. X-1, X-4, X-5. [pmid: 19548461].
1102 Soldado F, et al. Fetoscopic release of extremity amniotic bands with risk of amputation. J Pediatr Orthop. 2009;29(3):290-293. X-3, X-4, X-5. [pmid: 19305282].
1103 Soldado F, et al. Fetal surgery of extremity amniotic bands: an experimental model of in utero limb salvage in fetal lamb. J Pediatr Orthop. 2009;29(1):98-102. X-3, X-4, X-5. [pmid: 19098655].
1104 Steffensen TS, et al. Massive pericardial effusion treated with in utero pericardioamniotic shunt in a fetus with intrapericardial teratoma. Fetal Pediatr Pathol. 2009;28(5):216-231. X-4, X-5. [pmid: 19842876].
1105 Sumie M, et al. Two cases of reversal of twin-twin transfusion syndrome diagnosed by measuring hourly fetal urine production. J Obstet Gynaecol Res. 2009;35(5):983-986. X-5. [pmid: 20149052].
1106 Sy ED, et al. Prognostic role of tumor-head volume ratio in fetal sacrococcygeal teratoma. Fetal Diagn Ther. 2009;26(2):75-80. X-5. [pmid: 19752518].
1107 Tang PH, et al. Magnetic resonance imaging of the fetal central nervous system in Singapore. Ann Acad Med Singapore. 2009;38(9):774-781. X-5. [pmid: 19816636].
1108 Tchirikov M. Successful tracheal occlusion using ultrathin fetoscopic equipment combined with real-time three-dimensional ultrasound. Eur Surg Res. 2009;43(2):204-207. X-4, X-5. [pmid: 19521091].
1109 Tsukimori K, et al. Ischemic ileal perforation in the donor of monochorionic twins complicated by twin-twin transfusion syndrome. Fetal Diagn Ther. 2009;26(3):173-176. X-4. [pmid: 19752512].
1110 Wagner N, et al. Prenatal diagnosis and management of a fetal intra-abdominal teratoma: a case report and review of the literature. Fetal Diagn Ther. 2009;26(3):170-172. X-4, X-5. [pmid: 19887767].
1111 Wataganara T, et al. Reverse twin-twin transfusion syndrome after fetoscopic laser photocoagulation of chorionic anastomoses: a case report. Fetal Diagn Ther. 2009;26(2):111-114. X-4. [pmid: 19752511].
1112 Wilson RD, et al. Sacrococcygeal teratomas: prenatal surveillance, growth and pregnancy outcome. Fetal Diagn Ther. 2009;25(1):15-20. X-5. [pmid: 19122459].
1113 Wilson RD, Johnson A, Ryan G. Current controversies in prenatal diagnosis 2: Should laser ablation of placental anastomoses be used in all cases of twin to twin transfusion. Prenat Diagn. 2009;29(1):6-10. X-1, X-3, X-4. [pmid: 19101952].
1114 Xu C, et al. Prenatal tetrandrine treatment can reverse the abnormal conditions in the lung of newborn with congenital diaphragmatic hernia. Med Hypotheses. 2009;72(5):570-573. X-1, X-4. [pmid: 19193494].
1115 Zachariah JP, et al. Right ventricle to pulmonary artery conduit augmentation compared with replacement in young children. Ann Thorac Surg. 2009;88(2):574-580. X-5. [pmid: 19632414].
1116 Zeidan S, et al. Intralobar sequestration associated with cystic adenomatoid malformation: diagnostic and thoracoscopic pitfalls. Surg Endosc. 2009;23(8):1750-1753. X-5. [pmid: 18855054].
1117 Zhang B, et al. Robotic patch-stabilizer using wire driven mechanism for minimally invasive fetal surgery. Conf Proc IEEE Eng Med Biol Soc. 2009;2009:5076-5079. X-5. [pmid: 19964857].
1118 Antinolo G, et al. Diagnosis and management of fetal intrapericardial Morgagni diaphragmatic hernia with massive pericardial effussion. J Pediatr Surg. 2010;45(2):424-426. X-4, X-5. [pmid: 20152367].
1119 Bawa M, Kannan NL. Even a single third trimester antenatal fetal screening for congenital anomalies can be life saving. Indian J Pediatr. 2010;77(1):103-104. X-5. [pmid: 19936663].
1120 Crisan LS, Kontopoulos EV, Quintero RA. Appraisal of the selectivity index in a cohort of patients treated with laser surgery for twin-twin transfusion syndrome. Am J Obstet Gynecol. 2010;202(2):157 e1-157 e5. X-5. [pmid: 19846057].
1121 Curran PF, et al. Prenatal steroids for microcystic congenital cystic adenomatoid malformations. J Pediatr Surg. 2010;45(1):145-150. X-6. [pmid: 20105595].
1122 Curran S, et al. Reflectance spectrometry for real-time hemoglobin determination of placental vessels during endoscopic laser surgery for twin-to-twin transfusion syndrome. J Pediatr Surg. 2010;45(1):59-64. X-5. [pmid: 20105580].
1123 Fagiana AM, et al. Management of a fetal intrapericardial teratoma: a case report and review of the literature. Congenit Heart Dis. 2010;5(1):51-55. X-4, X-5. [pmid: 20136858].
1124 Goldberg SP, et al. Surgical management of intrapericardial teratoma in the fetus. J Pediatr. 2010;156(5):848-849. 849 e1. X-4, X-5. [pmid: 20304430].
1125 Harrison MR. What if?... Why not. J Pediatr Surg. 2010;45(1):1-10. X-1, X-3, X-4. [pmid: 20120061].
1126 Kohl T, et al. Partial amniotic carbon dioxide insufflation (PACI) during minimally invasive fetoscopic surgery: early clinical experience in humans. Surg Endosc. 2010;24(2):432-444. X-5. [pmid: 19565298].
1127 Longaker MT. Regenerative medicine: a surgeon’s perspective. J Pediatr Surg. 2010;45(1):11-17. discussion 17–18. X-1, X-4, X-5. [pmid: 20105574].
1128 Mittal S, et al. Supratentorial neurenteric cysts-A fascinating entity of uncertain embryopathogenesis. Clin Neurol Neurosurg. 2010;112(2):89-97. X-1, X-4, X-5. [pmid: 19962230].
1129 Ruano R, et al. Fetal cystoscopy for severe lower urinary tract obstruction—initial experience of a single center. Prenat Diagn. 2010;30(1):30-39. X-5. [pmid: 19967749].
1130 Van Mieghem T, et al. Amniotic fluid markers of fetal cardiac dysfunction in twin-to-twin transfusion syndrome. Am J Obstet Gynecol. 2010;202(1):48 e1-48 e7. X-5. [pmid: 19801144].
1131 Zhao YY, et al. Application of fetoscopy in the management of monochorionic multiple pregnancies. Chin Med J (Engl). 2010;123(1):105-107. X-1, X-4. [pmid: 20137585].