# Sample Data Abstract Forms

Technical Brief on Maternal-Fetal Surgery: Abstract Review From

This is a sample abstract review form completed as part of the review of studies for this technical brief. The study’s first author and year, the abstractor’s initials, and a reference number are recorded at the top of the form. The form contains five inclusion/exclusion criteria questions that are answered by circling either yes, no, or cannot determine. The questions are: original research, study published in English, human study population, eligible study size equal to or greater than two, and related to one or more of 15 subject areas. The subject areas are: sacrococcygeal teratoma, congenital diaphragmatic hernia, congenital cystic adenomatoid malformation, bronchopulmonary sequestration, obstructive uropathy, myelomeningocele, twin-twin transfusion syndrome, cardiac malformations, hydrocephalus, ovarian cysts, amniotic band, maternal outcomes of maternal-fetal surgery, anesthesia care for maternal-fetal surgery, intraoperative maternal and fetal monitoring for maternal-fetal surgery, and other. The form then asks whether it should be retained for background/discussion, review of references, ethics, or other. An area for comments is located at the bottom of the form.

Technical Brief on Maternal-Fetal Surgery: Full-Text Review From

This is a sample full-text review form completed as part of the review of studies for this technical brief. The study’s first author and year, the abstractor’s initials, and a reference number are recorded at the top of the form. The form contains five inclusion/exclusion criteria questions that are answered by circling either yes, no, or cannot determine. The questions are: original research, study published in English, human study population, eligible study size equal to or greater than two, and related to one or more of 15 subject areas. The subject areas are: sacrococcygeal teratoma, congenital diaphragmatic hernia, congenital cystic adenomatoid malformation, bronchopulmonary sequestration, obstructive uropathy, myelomeningocele, twin-twin transfusion syndrome, cardiac malformations, hydrocephalus, ovarian cysts, amniotic band, maternal outcomes of maternal-fetal surgery, anesthesia care for maternal-fetal surgery, intraoperative maternal and fetal monitoring for maternal-fetal surgery, and other. The form asks whether the study provides 14 categories of data: operational definition of fetal diagnoses, type of surgery, maternal inclusion criteria, training of providers/specialized expertise and equipment in the study hospitals, study country, study size, study setting, study design with six possible answers, comparator used, length of followup, outcomes measured for fetus, outcomes measured for mother, adverse events/harms/safety issues reported for fetus, and adverse events/harms/safety issues reported for mother. The form then asks whether it should be retained for background/discussion, review of references, ethics, or other. An area for comments is located at the bottom of the form.