# Exact Search Strings

Table 1 PubMed search strategies (last updated May 12, 2010)

Preliminary search terms | | Preliminary search results
#1 General fetal surgery search | (fetus/surgery[mh:noexp] OR fetal heart/surgery[mh] OR fetal diseases/surgery[mh] OR fetal surgery[tiab]) AND eng[la] AND humans[mh] | 1,426
#2 Sacrococcygeal teratoma | (sacrococcygeal teratoma OR sacrococcygeal region[mh]) AND (fetus[tiab] OR fetal[tiab]) AND (surgery OR surgical OR fetoscopy OR fetoscopic) AND eng[la] AND humans[mh] | 138
#3 Congenital diaphragmatic hernia | (hernia, diaphragmatic[mh] OR diaphragmatic hernia[tiab]) AND (fetoscopy OR fetoscopic[tiab] OR “fetal therapies”[mh]) AND eng[la] AND humans[mh] | 68
#4 Congenital cystic adenomatoid malformation, bronchopulmonary sequestration | (cystic adenomatoid malformation of lung, congenital[mh] OR bronchopulmonary sequestration[mh] OR adenomatoid[tiab] OR bronchopulmonary sequestration[tiab]) AND (intrauterine[tiab] OR in utero[tiab] OR fetoscopy OR fetoscopic[tiab] OR “fetal therapies”[mh]) AND eng[la] AND humans[mh] | 136
#5 Obstructive uropathy | (uropathy[tiab] OR urologic diseases[mh] OR urinary tract[mh]) AND (fetoscopy OR fetoscopic[tiab] OR “fetal therapies”[mh]) AND eng[la] AND humans[mh] | 39
#6 Myelomeningocele | (meningomyelocele OR myelomeningocele) AND (intrauterine[tiab] OR in utero[tiab] OR fetoscopy OR fetoscopic[tiab] OR “fetal therapies[mh]”) AND eng[la] AND humans[mh] | 127
#7 Twin-twin transfusion syndrome | fetofetal transfusion[mh] AND (laser therapy[mh] OR fetoscopy OR fetoscopic OR “fetal therapies”[mh]) AND eng[la] AND humans[mh] | 300
#8 Cardiac malformations | (fetal heart[mh] OR heart[mh] OR heart septal defects[mh] OR hypoplastic left heart syndrome[mh] OR aortic valve stenosis[mh] OR pulmonary valve stenosis[mh] OR pulmonary atresia[mh]) AND (fetoscopy OR fetoscopic[tiab] OR “fetal therapies”[mh]) AND eng[la] AND humans[mh] | 74
#9 | #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 | 2,020
#10 | #9 AND letter[pt] | 119^*^
#11 | #9 AND comment[pt] | 78
#12 | #9 AND editorial[pt] | 39
#13 | #9 AND review[pt] | 485^**^
#14 | #9 AND news[pt] | 9
#15 | #9 AND practice guideline[pt] | 4
#16 | #9 NOT (#10 OR #11 OR #12 OR #13 OR #14 OR #15) | 1,364^***^

Key: [mh] Medical Subject Heading; [tiab] title/abstract; [la] language; [mh:noexp] MeSH heading, not exploded

* Note: 34 of these letters include case reports; these have been included in the EndNote database

** Note: 52 of these reviews include case reports; these have been included in the EndNote database.

*** The EndNote database includes these 1,364 references, along with the 34 letters with case reports and the 52 reviews with case reports, bringing the overall pool of items retrieved by the PubMed searches to 1,450.

Update EndNote database from 5/12/10 includes 37 new items added to the database since the previous search update on 1/13/10.