# Summary

Currently available neurothrombectomy devices offer intriguing treatment options in patients with acute ischemic stroke, although a paucity of high quality research currently exists. There remains a need for further research on the topic, including randomized controlled trials to determine the optimal device(s) to use, and the patient populations most likely to benefit from their use. Additionally, studies of neurothrombectomy devices against contemporaneous controls investigating whether these devices truly treat final health outcomes associated with stroke rather than improving recanalization alone are warranted. Results of ongoing studies will likely only begin to address some of these questions.