# Results

## Key Question 1 What are the different types of neurothrombectomy devices in use or in development for treatment of acute ischemic stroke?

1a What are the existing FDA indications for each device?
1b Which devices are being used off-label for this indication?
1c What is the status of FDA approval for each device?
1d What are the theoretical advantages and disadvantages of these devices compared to other treatment options?
1e What are the potential safety issues and harms associated with the use of these devices?
1f What is the extent of utilization of the different devices?

Neurothrombectomy devices are categorized into five broad classes, including clot retrievers, aspiration/suction devices, snare-like devices, ultrasonography technologies, and lasers. Table 1 lists the various classes and devices in those classes that were identified as potentially useful for thrombus removal in the neurovasculature. It specifies those devices that have an FDA indication for acute ischemic stroke treatment and those currently available for clinical use.

Table 1 Neurothrombectomy devices in use

Device Class | Company Name | FDA Indication | In Clinical Use?
Aspiration/Suction
Amplatz Thrombectomy | Ev3 Medical | Mechanical dissolution of thrombus within dialysis fistulae | No longer marketed
AngioJet | Possis | Breaking apart or removing of thrombus in peripheral veins or arterio-venous access conduits | Yes
NeuroJet | Possis | NA | No longer marketed
Oasis Thrombectomy | Boston Scientific | Removing thrombus from hemodialysis access grafts | No longer marketed
Penumbra | Penumbra, Inc | Revascularization of patients with acute ischemic stroke | Yes
Vasco +35 | Balt Extrusion | NA | Not in US
Clot Retriever
Attractor-18 | Boston Scientific | NA | No longer marketed
Catch | Balt Extrusion | NA | Not in US
In-Time | Boston Scientific | Retrieval of intravascular foreign objects in peripheral vasculature, neurovasculature and cardiovasculature | No longer marketed
MERCI | Concentric Medical | Restore blood flow in the neurovasculature | Yes
Phenox | Phenox GmbH | NA | Not in US
TriSpan | Boston Scientific | NA | No longer marketed
Ultrasonography
EKOS | EKOS Corporation | Infusion of fluids into peripheral vasculature | Yes
OmniWave | OmniSonics | Removal of thrombus and infusion of fluids into peripheral vasculature | No longer marketed
Snare
Alligator | Chestnut Medical Technologies, Inc | Peripheral and neurovasculature foreign body removal | Yes
Amplatz Gooseneck | Ev3 Medical | Retrieval and manipulation of atraumatic foreign bodies in coronary and peripheral cardiovascular system and the extra-cranial neurovascular anatomy | Yes
EnSnare Device | Merit Medical Systems, Inc. | Retrieval and manipulation of foreign objects in the cardiovascular system or hollow viscous | Yes
Neuronet | Boston Scientific | NA | No longer marketed
Soutenir | Solution | NA | Not in US
Laser
EPAR | Endovasix Inc. | NA | No longer marketed
LaTIS | Spectranetics | Removal of thrombus from vascular grafts | No longer marketed

EPAR=Endovascular Photoacoustic Recanalization; FDA=Food and Drug Administration; NA=not applicable; US=United States

The aspiration/suction devices include the Amplatz Thrombectomy, AngioJet, NeuroJet, Oasis Thrombectomy, Penumbra System, and Vasco +35. The Amplatz Thrombectomy Device (Ev3 Medical, Plymouth, MN) consists of a catheter, a small diameter impeller encased in a distal housing, and a driveshaft. The AngioJet (Possis Medical, Minneapolis, MN) contains an AngioJet catheter and a pump in one combined unit. High-pressure saline jets agitate the clot face creating clot fragments that are suctioned out through the catheter. The set includes a 3-port catheter manifold that allows for the administration of other fluids, such as contrast media, to be injected into the blood stream where the catheter is positioned. The NeuroJet (Possis Medical, Minneapolis, MN) is operated in the same manner as the AngioJet, but is a smaller catheter designed specifically for intracranial navigation. The Oasis Thrombectomy System (Boston Scientific, Natick, MA) uses high velocity saline streams to microfragment and remove thrombus. The Penumbra System (Penumbra, Alameda, CA) consists of three devices: a reperfusion catheter, a separator and aspiration tubing. Once a guide wire is passed through the clot, the separator is advanced and the aspiration pump is turned on. Continuous aspiration-debulking is facilitated by advancing and withdrawing the separator through the reperfusion catheter. If residual clot remains, a second system for direct thrombus extraction via a thrombus removal ring can be used. Of note, the latter mentioned direct thrombus extraction component of the Penumbra System was not included in the FDA clearance. The Vasco +35 (Balt Extrusion, Montmorency, France) is a dedicated aspiration device with a blunt tip.

The clot retriever devices include the Attractor-18, Catch, In-Time, MERCI, Phenox, and TriSpan devices. The Attractor-18 device (Boston Scientific, Natick, MA) is a fiber-based retriever that contains a radiopaque distal platinum coil with a wire tip. Radiolucent fibers are wound with a radiopaque distal platinum marker and attached to the distal wire tip. The Catch device (Balt Extrusion, Montmorency, France) consists of a self-expanding basket-like design that is fixed on a pusher wire. The distally closed self-expanding nitinol cage is positioned in an insertion tube and delivered through a braided 2.4-Fr microcatheter. The In-Time device (Boston Scientific, Natick, MA) consists of a braided catheter shaft with a radiopaque basket attached to the end of the catheter. Unlike some other devices, it does not have a specific mechanism to capture the embolus. The MERCI clot retriever (Concentric Medical, Mountain View, CA) is a flexible, tapered nitinol core wire with the distal end shaped into a helix and attached with polymer filaments. The device also includes a torque device to facilitate manipulation and an insertion tool to introduce the retriever into the microcatheter. The Phenox Clot Retriever (Phenox GmbH, Bochum, Germany) consists of a highly flexible nitinol/platinum alloy compound core wire surrounded by stiff polyamide microfilaments in a conical shape. These filaments have an increasing diameter distally and are resistant to unraveling. More recent generations of this device incorporate a nitinol cage allowing it to trap thrombi with firmer consistency. The TriSpan device (Target Boston Scientific, Natick, MA) consists of three nitinol loops in a neck bridge design.

The ultrasonography devices include the EKOS and OmniWave systems. The EKOS system (EKOS, Bothell, WA) has a small ultrasound transducer at the tip of the device and a port to administer medications at the site of occlusion. The ultrasound waves increase the permeability of the clot in order to speed up the effect of IA thrombolytic agents. The OmniWave Endovascular System (Omnisonics Medical Technologies, Wilmington, MA) is a catheter-based system that directs low-power ultrasonic energy through a catheter wire creating bubbles that fracture the thrombus without damaging vessel walls.

The snare devices identified included the Alligator, Amplatz Gooseneck, EnSnare Device, Neuronet and Soutenir. The Alligator device (Chestnut Medical Technologies, Menlo Park, CA) is a retriever with grasping jaws attached to the tip of a flexible wire. It is designed to be used in conjunction with an existing microcatheter. The Amplatz Goosneck kit (Ev3 Medical, Plymouth, MN) contains a microsnare, microcatheter, a microsnare introducer and a torque device. The microsnare is constructed of a nitinol cable and gold plated tungsten loop. The catheter contains a platinum-iridium radiopaque marker band. The EnSnare system (Angiotech Technologies, Inc, Gainesville, FL) consists of three interlaced, tulip-shaped nitinol loops that open distally. The Neuronet device (Boston Scientific, Natick, MA) is a microguide-based nitinol self-expanding basket design with a crisscrossing portion that tapers to a platinum-tipped wire. The Soutenir device (Solution, Yokohama, Japan) is a basket-shaped microsnare consisting of four microwires which are 3-dimensionally configured with platinum coils on either end.

The lasers identified included the EPAR and LaTIS devices. The Endovascular Photo-Acoustic Recanalization (EPAR, Endovasix, Belmont, CA) is a mechanical clot-fragmentation device based on laser technology. Photonic energy is converted to acoustic energyat the fiberoptic tip through creation of microcavitation bubbles, emulsifying the thrombus which is then suctioned out. The LaTIS laser device (Spectanetics, Colorado Springs, CO) uses a laser at its tip to slowly inject contrast material creating a heating of the clot to the point where it breaks down.

### Key Question 1a What are the existing FDA indications for each device?

The approval process for medical devices varies from that of pharmacologic agents. The FDA’s CDRH handles the regulation of medical devices both premarket and postmarket.37 As such, neurothrombectomy devices are reviewed and cleared through the 510(k) premarket notification process.37,42 In order for a device to receive clearance through a 510(k) process, the manufacturer must demonstrate that the new device is substantially equivalent in safety and effectiveness to a Class II device that is already on the market for a particular indication. Most commonly, devices receive clearance based on nonclinical testing with little to no clinical data.37 The FDA does not mandate which study designs should be used, as long as the methods are scientifically sound. The FDA recommends that neurothrombectomy devices for the treatment of acute ischemic stroke assess effectiveness at 30-and 90 -days postintervention using any appropriate, validated disability or neurologic impairment scale.37 The selection of the most appropriate clinical endpoints and statistical tests varies depending on the device and study design used. The FDA also recommends reporting revascularization success using the TIMI grading of blood flow both before and after use of the specified device.

The FDA-cleared indications for neurothrombectomy devices included in this review can be found in Table 1. The MERCI retriever and the Penumbra System are the only devices with FDA clearance for the treatment of patients with an acute ischemic stroke. The MERCI retriever “is intended to restore blood flow in the neurovasculature by removing thrombus in patients experiencing ischemic stroke (who are ineligible for treatment with IV rt-PA or who fail IV rt -PA therapy).”39,42 The Penumbra system is used for the “revascularization of patients with acute ischemic stroke secondary to intracranial large vessel occlusive disease (in the internal carotid, middle cerebral—M1 and M2 segments, basilar, and vertebral arteries) within 8 hours of symptom onset.”42

A total of ten identified devices have FDA-cleared indications through the 510(k) process but not for acute ischemic stroke. The In-Time, Alligator, Amplatz Gooseneck, and EnSnare devices are cleared for the retrieval of intravascular foreign objects either in general or in the peripheral vasculature and neurovasculature. The EKOS and OmniWave systems are cleared for the infusion of fluids into the peripheral vasculature. The LaTIS laser and Oasis Thrombectomy System are cleared for the removal of thrombi from vascular or hemodialysis access grafts. The Amplatz Thrombectomy Device is cleared for dissolution of thrombi within dialysis fistulae.

### Key Question 1b Which devices are being used off-label for this indication?

A total of five devices included in this review are available for clinical use in the United States but do not have FDA-cleared indications for the treatment of acute ischemic stroke. The remaining devices included in this review are either no longer marketed or are only available in countries outside of the United States.

### Key Question 1c What is the status of FDA approval for each device?

The MERCI retriever and Penumbra System have FDA clearance for acute ischemic stroke. We did not identify any other device pending FDA review for such approval at this time. Multiple generations of the MERCI retriever have received FDA approval. The first-generation devices included the X5 and X6 which used nitinol wires with a helical shaped distal tip with tapering coil loops. The second-generation devices included the L4, L5, and L6 and differed from the X-series by including a system of arcading filaments attached to a nontapering helical nitinol coil. The third-generation V-series devices incorporate features of both the X-and L -series devices and have a more linear configuration with a slight distal taper and polymer filaments to help capture loose clot debris. The retriever is deployed distal to the clot using a microcatheter and balloon guide wire. The balloon is inflated and the retriever is slowly pulled back to capture the clot in the coil loops. The retriever and microcatheter are then slowly withdrawn to remove the clot. The Penumbra System is different in that it utilizes a unique microcatheter and separator-based thrombus debulking approach. The separator is deployed through a reperfusion catheter, then advanced and retracted at the proximal margin of the primary occlusion. This continuous motion facilitates aspiration by reducing the overall clot burden. This is followed by the use of aspiration tubing and a pump that is used in conjunction with the reperfusion catheter to remove the thrombus particles from the neurovasculature.

### Key Question 1d What are the theoretical advantages and disadvantages of these devices compared to other treatment options?

Neurothrombectomy devices for the treatment of patients with acute ischemic stroke offer several advantages over pharmacologic agents.40 Use of these devices allows patients to avoid use of pharmacologic thrombolysis agents, thereby presumably minimizing the risk for ICH. Additionally, treatment of patients with neurothrombectomy devices for acute ischemic stroke can be extended beyond the 3-hour window from symptom onset, beyond which thrombolytics cannot typically be used. Moreover, the uses of some devices fragment the thrombus occlusion increasing the surface area of the clot, allowing for improved accessibility of thrombolytic agents. The neurothrombectomy devices may also provide more rapid recanalization than thrombolytics as well as provide a treatment option for thrombi more resistant to fibrinolytic breakdown. As such, neurothrombectomy approaches are available as an option for patients who have either a contraindication to pharmacologic thrombolysis, such as recent surgery or abnormal hemostasis or are late in their presentation. This includes patients with occlusions of large cerebral vessels that have been shown to respond poorly to IV rtPA use.32 Parenthetically, providing adjunctive neurothrombolytic device treatment may be essential for accomplishing successful thrombolysis. It is possible that the use of neurothrombectomy devices would result in lower ICH rates than systemic thrombolytic therapy. This was supported by the results of the Multi-MERCI study,43 which reported a symptomatic ICH rate of 2.4 percent as compared with the 10 percent rate seen in the PROACT-II35 study with systemic thrombolysis although the different definitions for ICH used in these investigations may explain some of the discrepancies in event rates seen in these trials.

The disadvantages of the neurothrombectomy devices include the technical difficulty of navigating mechanical devices into the intracranial circulation, direct trauma to the neurovasculature (including vasospasm, vessel dissection, perforation, or rupture), and fragmentation of thrombi causing distal embolization into previously unaffected vessels and cerebral territories.40

### Key Question 1e What are the potential safety issues and harms associated with the use of these devices?

As stated above, the main safety concern with the use of neurothrombectomy devices is direct trauma to the neurovasculature as a consequence of the procedure. This can result in vasospasm, vessel dissection, perforation, or vessel rupture. Vasospasm with neurothrombectomy devices is likely secondary to vessel irritation.44 This can lead to vessel narrowing and lower chances of achieving recanalization. Vessel dissection is caused by the passage of the catheter back and forth in the vessel lumen. This risk can be minimized when the device is advanced over a guidewire. In addition, a potential risk for thrombus fragmentation and distal embolization into previously unaffected vessels and cerebral territories exists. An additional safety concern with the use of neurothrombectomy devices is the risk for ICH (both symptomatic and asymptomatic). While early studies suggested that ICH may be a concern with device use,45 more recent prospective study data refute these findings although differing definitions and populations limit the indirect comparison of data cross these studies.46,47 Off-protocol use of other devices or thrombolytics in acute ischemic stroke has occurred in these non-randomized studies of neurothrombectomy devices which may increase the reported rate of symptomatic ICH.

In addition to safety concerns of the device itself, the procedure the patients undergo carries inherent risks as well. Nichols and colleagues showed that intubation and heavy sedation was associated with worse outcomes, using data from the IMS I and II trials.48

### Key Question 1f What is the extent of utilization of the different devices?

Information on the utilization of various neurothrombectomy devices is lacking. One estimate provide by the manufacturer the MERCI retriever (Concentric Medical, Inc) suggested that their device has been used more than10,000 times for the treatment of acute ischemic stroke.49 No information regarding the time period or geographic area (e.g. Unites States only) for this data was provided. Information with other devices included in this review was not available.

## Key Question 2 From a systematic scan of studies of different types of neurothrombectomy devices, what are the type(s) of devices, study designs and sizes, patient characteristics, comparators used in comparative studies, lengths of follow-up, concurrent or prior therapies, outcomes measured, and adverse events, harms, and safety issues reported?

2a Type(s) of devices
2b Study design and size
2c Patient characteristics
2d Comparator used in comparative studies
2e Length of follow-up
2f Concurrent or prior therapy
2g Outcomes measured
2h Adverse events, harms and safety issues reported

### Literature Selection

Our systematic literature scan yielded a total of 2,054 citations, 378 of which were retrieved for full-text review (Figure 2). Ultimately, 87 reports were included in the literature scan. Appendix B lists the citations of eligible and excluded reports (at the full-text review stage), respectively.

Figure 2 PRISMA style flow chart of report inclusion and exclusion

This PRISMA style flow chart delineates the dispensation of records in the technical brief. In the identification stage, 2,033 records were identified through the literature search and 21 records were identified through other sources. After duplicates were removed, 1,626 records were screened and 1248 subsequently excluded. Thus 378 full text articles were assessed for eligibility and 291 were excluded for the following reasons: 25 were not in humans, 39 were not in English, 18 were not in the neurovasculature, 133 did not define the specific device used, 27 were not in acute stroke, 18 were not attributable to the device, 9 full text articles could not be obtained, and 22 were duplicate reports. Thus, 87 studies were included in qualitative synthesis.

Of the included reports, 18 were prospective single-arm studies, 7 were non-comparative retrospective studies enrolling consecutive patients and 59 were case series or case reports. The 62 case series and case reports. (Table 2) Throughout the rest of this technical brief, we will typically discuss prospective and retrospective studies separately from case series and case reports.

Table 2 Number of reports for each neurothrombectomy device stratified by type of study

Device Class | Number of Reports | | | | Total (n):
Device Class | Prospective, Single-Arm (n) | Non-Comparative Retrospective^*^ (n) | Case Series (n) | Case Reports (n) | Total (n):
Aspiration/Suction
AngioJet | 1 (12) | - | 3 (10) | 4 (4) | 8 (26)
Penumbra | 4 (204) | 3 (173) | 1 (5) | 3 (3) | 11 (385)
Clot Retriever
Attractor-18 | - | - | - | 1 (1) | 1 (1)
Catch | - | - | 1 (2) | - | 1 (2)
In-Time | - | - | 1(2) | 1 (1) | 2 (3)
MERCI | 6 (491) | 4 (220) | 12 (58) | 19 (19) | 41 (788)
Phenox | 1 (45) | - | 1 (2) | - | 2 (47)
TriSpan | - | - | 1(6) | - | 1 (6)
Ultrasonography
EKOS | 2 (49) | - | - | 1 (1) | 3 (50)
Snare
Alligator | - | - | 1 (6) | 2 (2) | 3 (8)
Amplatz Gooseneck | 1 (9) | - | 6 (29) | 4 (4) | 11 (42)
Neuronet | 1 (5) | - | 1(4) | 4 (4) | 6 (13)
Soutenir | - | - | 1 (2) | 1 (1) | 2 (3)
Device Not Specified | - | - | 4 (27) | 1 (1) | 5 (28)
Laser
EPAR | 1 (34) | - | - | - | 1 (34)
LaTIS | 1 (2) | - | - | - | 1 (2)
Total: | 18 (851) | 7 (393) | 33 (154) | 41 (41) | 99 ^ (1438)

EPAR=Endovascular Photoacoustic Recanalization

* Must have enrolled consecutive patients

^ Adds up to greater than the total of 82 reports depicted in the PRISMA flow sheet, since some reports provided data on multiple devices. A total of 16 prospective, 7 retrospective and 59 unique case series/reports were identified.

In addition to 87 identified reports, we identified eleven ongoing studies evaluating at least one neurothrombectomy device in acute ischemic stroke. (Table 3)

Table 3 Summary of ongoing studies of neurothrombectomy devices for ischemic stroke

ClinicalTrials.gov Identifier | Title | Anticipated Completion Year | Device(s) evaluated | Design/ Projected N | Inclusion Criteria | Endpoint(s)
NCT01088672 | Thrombectomy REvascularization of Large Vessel Occlusions in Acute Ischemic Stroke (TREVO) | 2010 | Trevo | P,O (N=50) | NIHSS: 8–30 (and mRS≤1) Symptom onset: < 8 hours Occlusion: ICA, MCA, BA, VA | mRS, death, TICI, NIHSS, SICH, SAEs
NCT00478478 | Merci Registry - Real World Use of the Merci Retrieval System in Acute Ischemic Stroke | 2010 | MERCI | P,O (N=1000) | Revascularized with MERCI | mRS, death, TIMI, NIHSS, discharge disposition
NCT00640367 | Intra-arterial Versus Systemic Thrombolysis for Acute Ischemic Stroke (SYNTHESIS EXP) | 2010 | Mechanical thrombolysis | RCT (N=350) | Able to initiate IV rtPA within 3 hours or IA thrombolysis within 6 hours of symptom onset | mRS, NIHSS
NCT01133223 | Safety and Efficacy of the Penumbra System in Acute Middle Cerebral Artery Stroke | 2010 | Penumbra | RCT (N=20) | Symptom inset: ≤3.5 hours Occlusion: MCA | mRS, death, sICH
NCT01062698 | Trial and Cost Effectiveness Evaluation of Intra-arterial Thrombectomy in Acute Ischemic Stroke | 2011 | MERCI, Penumbra, Catch, Solitaire | RCT (N=480) | NIHSS: 10–25 Symptom onset: <3 hours Occlusion: ICA, MCA, BA | mRS, BI, HRQoL
NCT01054560 | SOLITAIR FR With the Intention For Thrombectomy (SWIFT) Study | 2011 | Solitaire FR, MERCI | RCT (N=200) | NIHSS: 8–30 Symptom onset: <8 hours Occlusion: ICA, MCA, BA, VA IV rtPA: Ineligible/failed | mRS, death, TIMI, NIHSS, BI, ICH
NCT00963989 | Imaging Guided Patient Selection for Interventional Revascularization Therapy | 2011 | Penumbra | P,O (N=200) | NIHSS: >10 Occlusion: ICA, MCA | mRS, death, NIHSS, TIMI, SICH, AICH, SAEs
NCT00389467 | Mechanical Retrieval and Recanalization of Stroke Clots Using Embolectomy (MR RESCUE) | 2013 | MERCI, Penumbra | RCT (N=120) | NIHSS: ≥6 Symptom onset: <8 hours Occlusion: ICA, MCA IV rtPA: Allowed <4.5 hours from symptom onset | mRS, death, NIHSS, global test statistic, hemorrhagic transformation, SAEs,
NCT00785161 | Penumbra Imaging Collaborative Study (PICS) | 2014 | Penumbra | P,O (N=2000) | Revascularized with Penumbra | mRS, death, TIMI, NIHSS, ICH, SAEs
NCT00359424 | Interventional Management of Stroke (IMS) III Trial | 2015 | EKOS, MERCI, Penumbra | RCT (N=900) | NIHSS: ≥10 at time of IV rtPA or an NIHSS 7- 10 Symptom onset: <3 hours from IV rtPA Occlusion: ICA, MCA, BA | mRS, death, NIHSS, BI, SICH, AICH
Not Registered | Pragmatic Ischemic Stroke Thrombectomy Evaluation (PISTE) | Not reported | Approved mechanical devices | RCT (N>200) | Symptom onset: <6 hours Occlusion: ICA, MCA | mRS, TIMI, infarct size, HRQoL, cost of care

AICH=asymptomatic intracerebral hemorrhage; BA=basilar artery; BI=Barthel Index; HRQoL=health-related quality-of-life; ICA=internal carotid artery; IV rtPA=intravenous recombinant tissue plasminogen activator; MCA=middle cerebral artery; mRS=modified Rankin Scale; NIHSS=National Institutes of Health Stroke Scale; P,O= prospective observational; RCT=randomized controlled trial; SAE=significant adverse event; SICH=symptomatic intracerebral hemorrhage; TIMI=Thrombolysis in Myocardial Infarction; VA=vertebral artery=

∝ During the peer review process of this Technical Brief, it was noted by a reviewer that the PISTE study the studies had been cancelled and was no longer recruiting patients.

### Emerging Technologies

Two emerging technologies related to the treatment of patients with ischemic stroke include the use of intracranial stents as well as various imaging techniques. Although not included in the main part of this review, the potential future role of these technologies deserves mention.

Intracranial stents have been evaluated as a method of providing immediate arterial recanalization which, as discussed previously, has been associated with improved clinical outcomes.22,50 The stents achieve luminal recanalizatio n by displacing emboli toward the arterial wall, similar to their use for cardiovascular indications. However, unlike coronary vessels, intracranial arteries are more prone to vessel wall dissection and perforation resulting from their lack of an extensive external elastic lamina as well as other factors.50 In addition, their permanent placement would necessitate long-term oral antiplatelet therapy to prevent potentially devastating restenosis. Despite these technical challenges, numerous reports have shown the benefits of stents both for salvage treatment in patients who have failed prior neurothrombectomy devices51 or those with large vessel occlusions who cannot receive either IV or IA rtPA therapy.52–54 In the Stent-Assisted Recanalization in Acute Ischemic Stroke (SARIS) trial, the Wingspan system (Boston Scientific) had reasonable initial safety and efficacy in 20 patients presenting within 8-hours of stroke symptom onset with a mean NIHSS of 14 and either a contraindication to IV rtPA or failure to improve 1 hour after receiving IV thrombolysis.55 Given the permanent nature of these devices, however, they do not meet the criteria of a neurothrombectomy device in that they are not intended to retrieve or destroy blood clots.37

However, recent and ongoing studies are evaluating the use of ‘retrievable’ stents that are meant to provide immediate recanalization, and then be removed along with clot trapped within the stent matrix. A brief review of the literature identified four early case reports that describe the use of intracranial stents as salvage therapy in patients who have failed conventional neurothrombectomy treatment.56–59 A prospective study, currently only available in abstract form, reports on the safety and efficacy of the Solitaire stent (ev3 Inc, Plymouth, MN) in 18 patients with acute ischemic stroke (Appendix Table 4C).60 Seventy two percent of patients receiving the Solitaire system as a thrombectomy device achieved recanalization (TICI grade 2–3 flow), with three (16.7 percent) reports of ICH and one (5.6 percent) vessel perforation.60 A more recent prospective, single-center pilot study by Castano and colleagues reported on the safety and efficacy of a retrievable stent in 20 patients with a large vessel occlusion acute ischemic stroke and were either refractory or ineligible for IV rtPA therapy (Appendix Table 4C).61 The stents were deployed for 1–2 minutes before retrieval, with 18 of 20 (90 percent) of patients achieving successful revascularization (defined as TICI grade 2–3 flow). Six patients (30 percent) had asymptomatic ICH while 2 patients (10 percent) experienced symptomatic ICH.61 This study used the Solitaire AB device (ev3 Inc, Plymouth, MN) which is a self-expanding stent system currently cleared by the FDA for use in treating intracranial aneurysms. This device differs from those discussed in the current Technical Brief in that it provides immediate recanalization while trapping portions of the clot within the stent matrix, which is self-expanding and fully retrievable. Most currently used devices, including the Merci and Penumbra systems remove clot as a method of recanalization. This line of products, currently being evaluated in ongoing trials, may provide a new method of restoring cerebral blood flow in patients presenting with acute ischemic stroke symptoms who are unlikely to benefit from standard therapies. The ongoing SWIFT trial is comparing the Solitaire TR device to the Merci system and will provide the first comparative effectiveness data on different neurothrombectomy treatments for acute ischemic stroke.

The use of cranial imaging techniques, including computed tomography (CT) and magnetic resonance (MR) perfusion technology, allows unique assessment of patient’s pathophysiology especially in the setting of acute large vessel occlusion. These tests may expand the breadth of eligible patients for neurothrombectomy device use.

### Key Question 2a Type(s) of devices

Based upon the FDA CDRH’s “Guidance for Industry and FDA Staff: Pre-Clinical and Clinical Studies for Neurothrombectomy Devices,”37 a neurothrombectomy device is intended to retrieve or destroy blood clots in the cerebral neurovasculature by mechanical (clot retriever, aspiration/suction, snare-like), laser, ultrasonography technologies or combinations of these technologies. Our literature scan identified at least one report of the use of neurothrombectomy device from each of 5 distinct device classes. (Table 4)

Table 4 Devices By Class Evaluated in At Least One Identified Report

Clot Retriever | Aspiration/Suction | Snare | Ultrasonography | Laser
Attractor-18 | AngioJet | Alligator | EKOS | EPAR
Catch | Penumbra System | Amplatz Gooseneck | | LaTIS
In-Time | | Neuronet
MERCI | | Soutenir
Phenox | | Non-specific device(s)
TriSpan

EPAR=Endovascular Photoacoustic Recanalization

### Key Question 2b Study design and size

#### Study Design

Our literature scan identified a total of 1,308 patients receiving a neurothrombectomy device for the treatment of acute ischemic stroke as part of 87 unique reports. Within the 87 publications/abstracts identified, a total of 100 unique device reports were available since some publications/abstracts reported data on more than one type of device. Table 2 above details the number of prospective single-arm and retrospective studies, case series and case reports identified for each neurothrombectomy device during our literature scan. The majority (75 of 100, 75 percent) of reports identified were in the form of case series or reports. Only 18 were prospective, single-arm studies and 7 were non-comparative, retrospective studies enrolling consecutive patients. These studies were published in full-text (74 percent) or abstract (26 percent) form. The oldest eligible report of a neurothrombectomy device was published in 2000. Fifteen of the 25 prospective or retrospective studies (60 percent) were published between 2008 and 2010. No randomized controlled trials comparing devices to an active control (thrombolytics or other neurothrombectomy device) were identified. However, seven randomized controlled trials of neurothrombectomy devices are currently in progress. (Table 3) Of these, six are evaluating the use of multiple neurothrombectomy devices, albeit not one device to another. Instead, these studies compare the use of neurothrombectomy devices to best medical therapy (with or without IV rtPA). The largest percentage of overall reports (40 percent) and prospective studies (31 percent) were for the MERCI clot retriever. The Penumbra System had a total of nine reports describing its use, of which three (33 percent of all Penumbra reports) were prospective in nature. For the off-label devices (all but MERCI and Penumbra) studied, the number of prospective studies in rank order from highest to lowest was EKOS (N=2), followed by AngioJet, Phenox, Amplatz Gooseneck, Neuronet, EPAR and LaTIS lasers (all had a N=1). The number of any type of report methodology by device (including prospective, retrospective, and case series/report) can be viewed in Table 2.

For studies, we also collected data on whether key effectiveness and/or safety data were assessed by a blinded investigator or in a core laboratory (as recommended in the FDA CDRH’s guidance document).37 Only 3 of 18 (17 percent) prospective and 1 of 7 (14 percent) of retrospective studies clearly stated they utilized blinded outcome assessment (Appendix D, Tables 1–3). Two prospective studies used the Penumbra system while the third used the EKOS system. The single retrospective study used the Merci system.

##### Sample Size

Table 5 summarizes all identified reports of neurothrombectomy devices by device classification. It provides the total number of patients treated with each device class as well as the study design utilized and endpoint(s) evaluated.

Table 5 Effectiveness evidence for neurothrombectomy devices (n=1,311) (Reported as prospective/retrospective/case series or reports)

| Devices
| | | Clot Retriever (n=847) | | | Aspiration/ Suction (n=411) | | | Snare (n=94) | | | Ultrasound Technology (n=50) | | | Laser (n=36)
| | | P | R | C | P | R | C | P | R | C | P | R | C | P | R | C
Reported Outcomes | Recanalization | Studies | 7 | 4 | 34 | 5 | 3 | 10 | 2 | 0 | 24 | 1 | 0 | 1 | 2 | 0 | 0
Reported Outcomes | Recanalization | Patients | 524 | 220 | 98 | 211 | 173 | 24 | 14 | 0 | 74 | 29 | 0 | 7 | 36 | 0 | 0
Reported Outcomes | mRS | Studies | 5 | 1 | 11 | 5 | 3 | 4 | 2 | 0 | 9 | 1 | 0 | 1 | 1 | 0 | 0
Reported Outcomes | mRS | Patients | 440 | 18 | 11 | 213 | 173 | 16 | 12 | 0 | 33 | 14 | 0 | 1 | 34 | 0 | 0
Reported Outcomes | Death # | Studies | 5 | 1 | 16 | 5 | 3 | 7 | 2 | 0 | 9 | 1 | 0 | 0 | 1 | 0 | 0
Reported Outcomes | Death # | Patients | 450 | 18 | 38 | 184 | 173 | 23 | 12 | 0 | 53 | 14 | 0 | 0 | 34 | 0 | 0
Reported Outcomes | NIHSS | Studies | 3 | 0 | 15 | 4 | 3 | 5 | 2 | 0 | 11 | 1 | 0 | 0 | 1 | 0 | 0
Reported Outcomes | NIHSS | Patients | 371 | 0 | 31 | 211 | 173 | 12 | 12 | 0 | 53 | 14 | 0 | 0 | 34 | 0 | 0
Reported Outcomes | BI | Studies | | | | | | | 1 | 0 | 0 | 1 | 0 | 0
Reported Outcomes | BI | Patients | | | | | | | 5 | 0 | 0 | 14 | 0 | 0
Reported Outcomes | GOS | Studies | | | | | | | | | | 1 | 0 | 0
Reported Outcomes | GOS | Patients | | | | | | | | | | 14 | 0 | 0

Darker shading represents more frequent evaluation or larger number of patient evaluated

BI=Barthel Index; C=case report/case series; GOS=Glasgow Outcome Scale; mRS=modified Rankin Scale; n=the total number of patients evaluated for any effectiveness or safety endpoint; NIHSS=National Institutes of Health Stroke Scale; P=prospective; R=retrospective

# Death included if patients were followed-up for any duration of time after hospital-discharge

In rank order by total number of patients evaluated from highest to lowest, clot retrievers (n=748) were the most common device classification studied, followed by aspiration or suction devices (n=383), snare-like devices (n=94), ultrasonography technologies (n=50) and lasers (n=36).

The size of prospective single-arm studies ranged from 2 to 164 patients, and retrospective studies ranged from 15 to 114 patients. (Table 6) The largest studies were those evaluating the MERCI clot retriever (numbers ranged from 18 and 164 patients) and the Penumbra System (numbers ranged from 15 to 125 patients). Both these devices had relatively large (>100 patients) clinical studies and “real-world” (retrospective) evaluations. Ongoing prospective observational studies plan to collect data on 2,000 to 3,000 additional patients utilizing each these two devices. Eight prospective studies (no retrospective studies) of various off-label neurothrombectomy devices were identified. Two evaluated an EKOS ultrasonography technology (numbers ranging from 14 to 35 patients). The six remaining studies each evaluated a different off-label device. The largest of these studies enrolled 45 patients and the smallest study enrolled only two.

Table 6 Distribution (median and range) of sample sizes for prospective and retrospective studies for each neurothrombectomy device

| | Study Design
| | Prospective, Single-Arm | | Non-Comparative Retrospective^*^
Device Class | No. of Reports (Prospective, Single-Arm/ Non-Comparative Retrospective^*^) | Median N | Range of N | Median N | Range of N
Aspiration/Suction
AngioJet | 1 (1/0) | 12 | - | - | -
Penumbra | 7 (4/3) | 29 | 23 to 125 | 53 | 15 to 105
Clot Retriever
MERCI | 10 (6/4) | 30 | 24 to 164 | 44 | 18 to 114
Phenox | 1 (1/0) | 45 | - | - | -
Ultrasonography
EKOS | 2 (2/0) | 25 | 14 to 35 | - | -
Snare
Amplatz Gooseneck | 1 (1/0) | 9 | - | - | -
Neuronet | 1 (1/0) | 5 | - | - | -
Laser
EPAR | 1 (1/0) | 34 | - | - | -
LaTIS | 1 (1/0) | 2 | - | - | -

EPAR=Endovascular Photoacoustic Recanalization, N=number of patients

* Must have enrolled consecutive patients

The remaining 74 of 99 (75 percent) identified reports, representing 59 of 82 (72 percent) unique citations, were either case series or case reports. In total, 191 patients were evaluated with a neurothrombectomy device in these case series or case reports. The number of patients receiving each neurothrombectomy device in a case series or case report as well as the combined number isdepicted in Table 7. The combined number of patients evaluated in a case series or report with a neurothrombectomy device ranged from 0 (EPAR and LaTIS lasers) up to 75. As with the prospective and retrospective studies, the MERCI clot retriever was the most commonly evaluated (n=77 patients in 31 reports). Case series and reports provide the majority of data on off-label use (n=109 patients in 39 reports) of potential neurothrombectomy devices to treat acute ischemic stroke.

Table 7 Distribution of sample sizes (total number of patients and range) in case series and reports for each neurothrombectomy device

| | Study Design
| | Case Series | Case Reports
Device Class | No. Reports (Case Series/Case Reports) | Total Patients N | Total Patients N | Combined Total N
Aspiration/Suction
AngioJet | 7 (3/4) | 10 | 4 | 14
Penumbra | 4 (1/3) | 5 | 3 | 8
Clot Retriever
Attractor-18 | 1 (0/1) | - | 1 | 1
Catch | 1 (1/0) | 2 | - | 2
In-Time | 2 (1/1) | 2 | 1 | 3
MERCI | 31 (12/19) | 58 | 19 | 77
Phenox | 1 (1/0) | 2 | - | 2
TriSpan | 1 (1/0) | 6 | - | 6
Ultrasonography
EKOS | 1 (0/1) | - | 1 | 1
Snare
Alligator | 3 (1/2) | 6 | 2 | 8
Amplatz Gooseneck | 10 (6/4) | 29 | 4 | 33
Neuronet | 5 (1/4) | 4 | 4 | 8
Device Not Specified | 5 (4/1) | 27 | 1 | 28
Soutenir | 2 (1/1) | 2 | 1 | 3
Laser
EPAR | - | - | - | -
LaTIS | - | - | - | -

EPAR=Endovascular Photoacoustic Recanalization, N=number of patients, No.=number

### Key Question 2c Patient characteristics

Both prospective and retrospective studies typically enrolled patients older than 18 years of age, with baseline NIHSS scores ≥8 (or ≥10), presenting within 8 hours of stroke symptom onset (or up to 24 hours for EKOS, EPAR or LaTIS laser if a posterior circulation occlusion was identified) and having a complete or near complete (TIMI 0–1)37 occlusion of a treatable large, intracranial vessel. Common exclusion criteria included advanced age (>80 years of age), large brain infarction, high risk of bleeding (including prothrombin time >15 seconds, hemorrhagic diathesis, coagulation factor deficiency, oral anticoagulation with international normalized ratio (INR) >3, use of heparin with partial thromboplastin time >2 times normal, platelets <30,000), severe or uncontrolled hypertension, glucose <50 mg/dL, and pregnancy. Studies also enrolled patients with contraindications to receive IVrtPA due to risks of adverse events (i.e., ICH), those reporting outside a 3-hour window (standard for studies at that time) from symptom onset to IV rtPA, or who failed (target vessel not recanalized as determined by immediate angiography following the procedure) IV rtPA treatment. The one exception was the EKOS study by Tomsick in 2008.19 The EKOS device is designed to infuse IA thrombolytic therapy, and in this study, the EKOS (Primo) device was used along with reduced dose IV rtPA within the first 3-hours of stroke symptoms. Tables 1D to 3D can be found in Appendix D and detail study-specific inclusion and exclusion criteria for prospective and retrospective studies.

Tables 8 and 9 below summarize key patient characteristics including age, gender, baseline NIHSS, symptom-to-angiography or device time and location of embolus/occlusion for studies which provided data. As a result of these inclusion/exclusion criteria, the mean/median baseline NIHSS range was fairly narrow across studies, ranging from 15 to 23. The range for mean/median age was 42 to 68 years, and studies enrolled between 20 percent and 57 percent females. In studies where data were provided, the majority of patients had pre-device TIMI 0 or 1 flow. Mean/median stroke symptom-to either angiography or device deployment time ranged from 141 to 388 minutes; all studies had a mean/median intervention time within the 8 hour time frame suggested by the FDA CDRH guidance for deploying a neurothrombectomy device.37 The location of the primary embolus was most commonly in an anterior vessel (14 studies enrolled >60 percent anterior occlusion patients). However, some studies focused heavily on posterior (vertebral and/or basilar) occlusions (two studies enrolled 100 percent vertebral or basilar occlusions). While we characterized studies by the proportion of anterior and posterior circulation lesions, it is important to note that not all anterior or posterior circulation lesions pose the same risk of stroke severity [e.g., while both classified as anterior, a more proximal occlusion in the distal ICA (carotid ‘T’) generally poses a higher risk than a smaller, more peripheral MCA-branch lesion]. Six studies were unclear about the location of occlusion. A limited number of patients with occlusions in other areas of the cerebral circulation were included in studies. Only 1 of 23 (4 percent) studies reported including patients with occlusions in these other areas.

Table 8 Distribution (median and range) of patient ages, baseline NIHSS, gender and symptom-to-angiography or device deployment time for each neurothrombectomy device in prospective and retrospective studies

Device Class | No. of Reports (Prospective, Single-Arm/Non-Comparative Retrospective^#^) | Mean or Median Age | | Mean or Median NIHSS^†^ | | Mean or Median Female (percent) | | Mean or Median Symptom-to-Angiography or Device Deployment Time (minutes)
Device Class | No. of Reports (Prospective, Single-Arm/Non-Comparative Retrospective^#^) | Median | Range | Median | Range | Median | Range | Median | Range
Aspiration/Suction
AngioJet | 1 (1/0) | 56 | - | 20 | - | 25 | - | - | -
Penumbra^*^ | 7 (4/3) | 62 | 58 to 66 | 18 | 14 to 21 | 48 | 40 to 66 | 180 | 141 to 312
Clot Retriever
MERCI^*^ | 10 (6/4) | 65 | 63 to 68 | 19 | 18 to 22 | 44 | 36 to 58 | 301 | 258 to 312
Phenox^*^ | 1 (1/0) | - | - | - | - | - | - | - | -
Ultrasonography
EKOS^*^ | 2 (2/0) | 64 | - | 18 | - | 50 | - | 331 | -
Snare
Amplatz Gooseneck | 1 (1/0) | 55 | - | 16 | - | - | - | 251 | -
Neuronet | 1 (1/0) | 42 | - | 20 | - | 20 | - | 388 | -
Laser
EPAR | 1 (1/0) | 68 | - | 19 | - | 50 | - | 382 | -
LaTIS^*^ | 1 (1/0) | - | - | 23 | - | - | - | 375 | -

EPAR=Endovascular Photoacoustic Recanalization; No.=number

* Data not reported in all studies for all characteristics

# Must have enrolled consecutive patients

† Data in this table represent the range of mean/median baseline NIHSS scores from studies included for each of the states devices. This does not reflect the total range of patients from each study.

Table 9 Distribution (median and range) of emboli location for each neurothrombectomy device in prospective and retrospective studies^#^

Device Class | No. of Reports (Prospective, Single-Arm/Non-Comparative Retrospective^#^) | Anterior Circulation Occlusion (percent) | | Posterior Circulation Occlusion (percent) | | Other Occlusion (percent)
Device Class | No. of Reports (Prospective, Single-Arm/Non-Comparative Retrospective^#^) | Median | Range | Median | Range | Median | Range
Aspiration/Suction
AngioJet | 1 (1/0) | 0 | - | 100 | - | 0 | -
Penumbra^*^ | 7 (4/3) | 80 | 57 to 88 | 20 | 9 to 43 | 0 | 0 to 3^‡^
Clot Retriever
MERCI^*^ | 10 (6/4)
Phenox^*^ | 1 (1/0) | 65 | - | 27^†^ | - | - | -
Ultrasonography
EKOS^*^ | 2 (2/0) | 71 | - | 29 | - | 0 | -
Snare
Amplatz Gooseneck | 1 (1/0) | 67 | - | 33 | - | 0 | -
Neuronet | 1 (1/0) | 0 | - | 100 | - | 0 | -
Laser
EPAR | 1 (1/0) | 65 | - | 35 | - | 0 | -
LaTIS^*^ | 1 (1/0) | 100 | - | 0 | - | 0 | -

EPAR=Endovascular Photoacoustic Recanalization; No.=number

* Data not reported in all studies for all characteristics

# Must have enrolled consecutive patients

† 8% of occlusions were combined anterior and posterior

‡ Other may include occlusions anywhere outside of the ICA, MCA, vertebral or basilar locations

Summarized in Tables 10 and 11 are baseline characteristics and location of embolic occlusions for patients studied in case series and case reports. While the majority of case series and case reports included patients that would typically meet prospective study inclusion criteria, a few enrolled patients outside these norms. Case series and reports included both pediatric patients and those greater than 80 years of age (case series/report age range: 6 to 90 years), both which were excluded in prospective and retrospective studies. Furthermore, a small number of case series and reports enrolled patients with baseline NIHSS scores below the typical enrollment threshold of 8 to 10 (case series/report NIHSS range: 0 to 42). Finally, some case series and reports for the Penumbra System, MERCI clot retriever, TriSpan clot retriever, In-Time clot retriever, and Neuronet and Amplatz Gooseneck snares, enrolled patients with symptom-to-angiography or device deployment times outside the 8 hour (480 minute) window used in prospective and retrospective studies of these devices (maximum time range was 1,200 minutes).Only studies of the EKOS, EPAR or LaTIS laser devices have utilized a device in patients with such prolonged symptom times (up to 24 hours from symptom onset), and only in patients with posterior occlusions.

Table 10 Distribution of patient ages, baseline NIHSS, gender and symptom-to-angiography or device deployment time for each neurothrombectomy device in case series and case reports

Device Class | No. of Reports (Case Series/Case Reports) | Age (years) | Baseline NIHSS | Female | Symptom-to-Angiography or Device Deployment Time (minutes)
Device Class | No. of Reports (Case Series/Case Reports) | Range | Range | n (percent) | Range
Aspiration/Suction
AngioJet | 7 (3/4)^*^ | 14 to 84 | 19 to 25 | 8 (62) | 10 to 270
Penumbra | 3 (1/2) | 28 to 59 | 15 to 42 | 2 (29) | 120 to 780
Clot Retriever
Attractor-18 | 1 (0/1) | 72 to 72 | 12 to 12 | 0 (0) | 380 to 380
Catch | 1 (1/0) | - | - | - | -
In-Time | 2 (1/1)^*^ | 16 to 72 | 14 to 28 | 1 (33) | 300 to 720
MERCI | 31 (12/19)^*^ | 6 to 90 | 6 to 40 | 25 (81) | 120 to 1020
Phenox | 1 (1/0) | 70 to 78 | - | 0 (0) | -
TriSpan | 1 (1/0) | 43 to 72 | 20 to 28 | 3 (50) | 240 to 1200
Ultrasonography
EKOS | 1 (0/1) | 19 to 19 | 15 to 15 | 1 (100) | -
Snare
Alligator | 3 (1/2)^*^ | 50 to 84 | 0 to 25 | 2 (100) | 60 to 480
Amplatz Gooseneck | 10 (6/4) | 37 to 90 | 10 to 30 | 16 (48) | 60 to 600
Neuronet | 5 (1/4)^*^ | 7 to 48 | 13 to 24 | 3 (75) | 360 to 600
Device Not Specified | 5 (4/1)^*^ | 33 to 79 | 7 to 27 | 4(40) | 240 to 354
Soutenir | 2 (1/1) | 49 to 78 | 19 to 33 | 0 (0) | 190 to 230
Laser
EPAR | - | - | - | - | -
LaTIS | - | - | - | - | -

EPAR=Endovascular Photoacoustic Recanalization; n=number of patients; No.=number

* Data not reported in all studies for all characteristics

Table 11 Distribution of emboli location for each neurothrombectomy device in case series and case reports

Device Class | No. of Reports (Case Series/Case Reports) | Anterior Circulation Occlusion n (percent)^#^ | Posterior Circulation Occlusion n (percent)^#^ | Other Occlusion n (percent)^#^
Aspiration/Suction
AngioJet | 7 (3/4) | 14 (50) | 1 (7) | 6 (43)
Penumbra | 3 (1/2) | 4 (57) | 3 (43) | 0
Clot Retriever
Attractor-18 | 1 (0/1) | 1 (100) | 0 | 0
Catch | 1 (1/0) | 2 (100) | 0 | 0
In-Time | 2 (1/1) | 0 | 3 (100) | 0
MERCI^*^ | 31 (12/19) | 21 (82) | 10 (16) | 1 (2)
Phenox | 1 (1/0) | 1 (50) | 1 (50) | 0
TriSpan | 1 (1/0) | 0 | 6 (100) | 0
Ultrasonography
EKOS | 1 (0/1) | 1 (100) | 0 | 0
Snare
Alligator | 3 (1/2) | 8 (100) | 0 | 0
Amplatz Gooseneck^*^ | 10 (6/4) | 14 (58) | 10 (42) | 0
Neuronet^*^ | 5 (1/4) | 2 (50) | 2 (50) | 0
Device Not Specified^*^ | 5 (4/1) | 12 (92) | 1 (8) | 0
Soutenir | 2 (1/1) | 3 (100) | 0 (0) | 0
Laser
EPAR | - | - | - | -
LaTIS | - | - | - | -

n=number of patients; No.=number

* Data not reported in all studies for all characteristics

# Includes only patients with reported data; 3 patients had two device types deployed during a single event

The location of emboli reported in evaluable patients (n=156) assessed in case series and case reports was predominantly in the anterior circulation (72 percent), followed by the posterior circulation (24 percent), and in other parts of the neurovasculature (4 percent).

### Key Question 2d Comparator used in comparative studies

No direct human comparative studies were identified during our scan of the neurothrombectomy literature. Existing direct device-to-device comparisons have come in the form of in vitroor animal s tudies and are outside the scope of this technical brief.62,63 Studies are underway that are allowing the use of multiple neurothrombectomy devices; however, these studies compare the use of neurothrombectomy devices to best medical therapy (with or without IV rtPA). The ongoing SWIFT trial is prospectively examining the comparative effectiveness of two different neurothrombectomy devices in an acute ischemic stroke population. This is the first head-to-head randomized trial comparing these devices with enrollment expected to complete at the end of 2010.

Nogueira and colleagues64 compared the percentage of patients experiencing a good outcome (defined using the mRS) in several neurothrombectomy studies to those of IV or IA rtPA arms of other studies. Good outcomes occurred in 28 percent, 36 percent, and 25 percent of patients receiving neurothrombectomy therapy (mRS ≤2) in the MERCI,46 Multi -MERCI,47 and Penumbra Pivotal Stroke Trial65 as compared to 39 percent, 52 percent, and 40 percent of patients in the NINDS rtPA (IV rtPA),25 ECASS III (IV rtPA), 27 and PROACT II (IA rtPA) 35 studies (mRS<2), respectively, despite higher rates of successful recanalization as compared to those receiving IV or IA rtPA. Patients receiving neurothrombectomy device therapy also exhibited higher rates of mortality. The authors postulated, however, that differences between patient populations across studies such as clot location and burden, baseline stroke severity, and time from symptom onset to treatment may have driven these differences, not the inferiority of neurothrombectomy devices. Moreover, changes in standards of stroke care over time may have played a role as well.

In one study, patients (n=121) from the IA thrombolytic arm of the PROACT II trial were compared only to patients (n=142) in the neurothrombectomy arms of the MERCI and Multi-MERCI trials who would have been eligible had they enrolled in PROACT II.18 By selecting and analyzing only comparable patients, similar rates of good outcome and mortality resulted. This supports the hypothesis that differences in study design and baseline patient characteristics between rtPA and neurothrombectomy trials account for differences in outcomes. Based upon findings such as these, we caution reviewers or decision makers against making indirect comparisons between studies of different recanalization strategies in an attempt to determine their comparative effectiveness or safety.

### Key Question 2e Length of follow-up

The FDA CDRH guidance document for neurothrombectomy devices suggests that recanalization success should be assessed following the procedure, and that clinical effectiveness should be assessed at 30-and 90 -days.37 All studies reported recanalization success after neurothrombectomy device deployment. The longest duration of follow-up in the majority of studies reporting effectiveness outcomes (i.e., mRS or death) was either 30-or 90 -days post-procedure. (Table 12) The timing of NIHSS evaluation was more variable with the longest duration of follow-up ranging from 24-hour to 90-days post-procedure. Safety endpoints were typically monitored over shorter lengths of time, such as the first 24-hours or until discharge.

Table 12 Longest duration of follow-up in prospective, single-arm or retrospective studies of neurothrombectomy devices

Device | Outcome Reporting at 30-Days | | | Outcome Reporting at 90-Days | | | Outcome reporting at Other Times
Device | NIHSS^*^ | mRS≤2 | Death | NIHSS | mRS≤2 | Death | NIHSS | mRS≤2 | Death
Aspiration/Suction
AngioJet (No.=1) | - | - | - | - | No.=1 | No.=1 | - | - | -
Penumbra (No.=7) | No.=3 | No.=2 | No.=2 | No.=1 | No.=5 | No.=5 | No.=3∂ | - | -
Clot Retriever
MERCI (No.=10) | - | No.=1 | No.=1 | No.=1 | No.=4 | No.=4 | No.=1∝ | - | -
Phenox (No.=1) | - | - | - | - | - | - | - | - | -
Ultrasonography
EKOS (No.=2) | - | - | - | No.=1 | No.=1 | No.=1 | - | - | -
Snare
Amplatz Gooseneck (No.=10) | - | - | - | No.=1 | No.=1 | No.=1 | - | - | -
Neuronet (No.=1) | - | - | - | No.=1 | No.=1 | No.=1 | - | - | -
Laser
EPAR (No.=1) | No.=1 | No.=1 | No.=1 | - | - | - | - | - | -
LaTIS (No.=1) | - | - | - | - | - | - | - | - | -

EPAR=Endovascular Photoacoustic Recanalization; mRS=modified Rankin scale; NIHSS=National Institutes of Health Stroke Scale; No.=number of studies

* Includes any method of reporting of NIHSS (i.e., NIHSS decrease ≥4, 50% drop, NIHSS 0–1 or improved by at least 10-points at discharge, etc.)

∝ Data provided at 24 hours

∂ Data provided at hospital discharge for all three studies

The reporting of follow-up outcomes in case series and case reports was variable. Of the 71 total device reports, nearly half did not report data on effectiveness or safety outcomes after patient discharge. In those reports that did, length of follow-up ranged from 6 weeks to 24 months; the most commonly reported length of follow-up was 90-days.

### Key Question 2f Prior or concurrent therapy

Based upon the NINDS rtPA Stroke Study results,25 IV rtPA treatment has become the standard-of-care treatment for those with acute ischemic stroke presenting within 3 hours (up to 4.5 hours in some patients) of symptom onset.30 Neurothrombectomy studies identified have thus focused, through inclusion and exclusion criteria, on either patients contraindicated to receive IV rtPA due to risks of adverse events (i.e., ICH), those presenting outside the recommended 3 hour window, or who were refractory or failed IV rtPA treatment. Consequently, the use of IV rtPA among studies ranged from 0 percent (studies required patients be ineligible) to 100 percent (studies required patients to have failed IV rtPA therapy prior to enrollment). The adjunctive use of thrombolysis in prospective or retrospective studies of neurothrombectomy devices is depicted in Table 13.

Table 13 Adjunctive thrombolysis use in prospective, single-arm or retrospective studies of neurothrombectomy devices

Device Class | No. of Reports (Prospective, Single-Arm/Non-Comparative Retrospective^*^) | Intravenous Thrombolysis n/N (percent) | Intra-arterial Thrombolysis n/N (percent)
Aspiration/Suction
AngioJet | 1 (1/0) | 0/12 (0) | 5/12 (42)
Penumbra | 7 (4/3) | 88/225 (39)^#^ | 110/297 (37)^†^
Clot Retriever
Attractor-18 | - | - | -
Catch | - | - | -
In-Time | - | - | -
MERCI | 10 (6/4) | 53/446 (12)^‡^ | 95/614 (15)
Phenox | 1 (1/0) | NR | NR
TriSpan | - | - | -
Ultrasonography
EKOS | 2 (2/0) | 35/49 (71) | 49/49 (100)
Snare
Alligator | - | - | -
Amplatz Gooseneck | 1 (1/0) | 0/9 (0) | 4/9 (44)
Neuronet | 1 (1/0) | 0/5 (0) | 3/5 (60)
Soutenir | - | - | -
Device Not Specified | - | - | -
Laser
EPAR | 1 (1/0) | 1/34 (3) | 16/34 (47)
LaTIS | 1 (1/0) | 0/2 (0) | 0/2 (0)

n=number of patients receiving therapy; N=number of evaluable; No.=number

* Must have enrolled consecutive patients

# One out of seven studies did not report data (PPST, 2009)

† One of seven studies did not report data (Frei, 2009)

‡ Two of 10 studies did not report data (Madison, 2008; Jo, 2008)

The one exception was the EKOS study by Tomsick in 2008.^19^ The EKOS device is designed to infuse IA thrombolytics and in this study, the EKOS (Primo) device was used along with reduced dose IV rtPA within the first 3 hours of stroke symptoms.

Concurrent or rescue therapies in identified studies, case series and reports included IA thrombolytics, cerebral artery angioplasty and stenting. In most studies, the decision to use these strategies was left to the discretion of the investigator/treating neurologist.

### Key Question 2g Effectiveness outcomes measured

The FDA CDRH guidance document suggests that recanalization success be assessed using TIMI grading of flow after treatment with a neurothrombectomy device.37 While recanalization is considered an intermediate outcome, there is an abundance of data demonstrating that achieving recanalization results in favorable final health outcomes. In a meta-analysis of 53 studies encompassing over 2,000 patients, Rha and colleagues demonstrated that at 3 months, favorable functional outcomes were more frequent in recanalized vs. non-recanalized patients (OR 4.43, 95 percent CI 3.32 to 5.91), and mortality was reduced (OR 0.24, 95 percent CI 0.16 to 0.35).22 Furthermore, the guidance document recommends that clinical effectiveness should be assessed using a validated neurologic impairment scale, disability measure, or handicap scale. Examples of FDA-recommended measures include the mRS, NIHSS score, Barthel Index, and GOS.37

Table 5, previously referenced and provided above, summarizes all identified reports of neurothrombectomy devices by device classification and the effectiveness endpoint(s) evaluated. The figure uses a density-shading scheme, so that the most common effectiveness endpoints have the greatest degree of shading. The figure demonstrates that recanalization, mRS, NIHSS, and death are the most commonly assessed endpoints. Despite being listed in the CDRH’s guidance document,37 few reports assessed the Barthel Index or GOS.

Recanalization success was typically defined as establishment of TIMI grade II (partial) or III (complete) flow within the target (or all) vessels upon angiography following the procedure. A newer cerebral grading scale (the Thrombolysis in Cerebral Infarction or TICI scale) was used far less frequently, as were neuroimaging measures (e.g., final stroke lesion size and perfusion neuroimaging technologies). All prospective or retrospective studies reported recanalization results. Figures 1D to 3D in Appendix D depict the proportion of patients achieving partial or complete recanalization in these studies. The figures are stratified by device, with separate figures for each of the FDA-cleared devices (Penumbra System and MERCI clot retriever) and for off-label devices.

The NIHSS score was often assessed in reports of neurothrombectomy devices, with a decrease of 4 points commonly defined as a clinically important improvement in neurological outcome.37 NIHSS outcome data, in some form, was presented in 12 of 23 (52 percent) identified prospective or retrospective studies. For studies assessing clinical effectiveness using mRS, successful treatment was typically defined as the proportion of patients having a ‘good’ outcome (score of 0–2). Individual study achievement of mRS≤ 2 was presented in 16 of 23 (70 percent) studies. Tables 1D to 3D in Appendix D depict the results of prospective or retrospective studies for the NIHSS, mRS≤ 2, as well as mortality after discharge endpoints. These effectiveness endpoints were reported in 22 percent, 56 percent and 56 percent of MERCI clot retriever, 100 percent, 100 percent and 100 percent of Penumbra System, and 50 percent, 50 percent and 63 percent of off-label device studies. As with recanalization, results are stratified by device, with separate figures for each of the FDA-cleared devices (Penumbra System and MERCI clot retriever) and for off-label devices.

Identified ongoing studies, as identified on www.clinicaltrials.gov appear to be collecting data on effectiveness/efficacy endpoints recommended in the FDA CDRH guidance document and similar to those assessed in completed studies.

### Key Question 2h Adverse events, harms, and safety issues reported

Current guidance suggests numerous different adverse event endpoints to be recorded in evaluations of neurothrombectomy devices.37 Table 14 below summarizes all identified reports of neurothrombectomy devices by device classification and the safety endpoint(s) evaluated. As with the effectiveness figure above, this figure uses a density-shading scheme so that the most common endpoints have the greatest degree of shading. The figure demonstrates that ICH, either symptomatic or asymptomatic, was the most commonly assessed adverse event, harm or safety issue. Other safety endpoints evaluated in the neurothrombectomy literature included: perforation/dissection, other types of hemorrhage (not intracerebral), thrombus formation proximal, adjacent or distal to the clot site, failure to deploy the device, device breakage/fracture and vasospasm. Tables 4D to 6D in Appendix D depict the proportion of patients per study experiencing an instance of symptomatic or asymptomatic ICH, other bleeding, perforation or dissection or thrombus formation in prospective or retrospective studies. These safety endpoints were reported in 56 percent, 56 percent, 22 percent, 22 percent and 22 percent of MERCI clot retriever, 100 percent, 83 percent, 33 percent, 50 percent and 50 percent of Penumbra System, and 63 percent, 38 percent, 0 percent, 63 percent and 38 percent of “off-label device studies, respectively. In addition, Table 7D in Appendix D provides data on the rate of device failure-to-deploy and device fracture or breakage in these same studies. These were infrequently reported in device reports, as were data on vasospasm.

Table 14 Safety endpoint evidence for neurothrombectomy devices (n=1,311) (Reported as prospective/retrospective/case series or reports)

| Devices
| | | Clot Retriever (n=847) | | | Aspiration/Suction (n=411) | | | Snare (n=94) | | | Ultrasound Technology (n=50) | | | Laser (n=36)
| | | P | R | C | P | R | C | P | R | C | P | R | C | P | R | C
Reported Adverse Events | SICH | Studies | 5 | 0 | 8 | 5 | 3 | 3 | 1 | 0 | 10 | 2 | 0 | 0 | 1 | 0 | 0
Reported Adverse Events | SICH | Patients | 382 | 0 | 39 | 213 | 173 | 10 | 7 | 0 | 37 | 49 | 0 | 0 | 34 | 0 | 0
Reported Adverse Events
Reported Adverse Events | AICH | Studies | 5 | 0 | 8 | 5 | 2 | 3 | 1 | 0 | 10 | | | | 1 | 0 | 0
Reported Adverse Events | AICH | Patients | 382 | 0 | 39 | 213 | 158 | 10 | 7 | 0 | 37 | | | | 34 | 0 | 0
Reported Adverse Events
Reported Adverse Events | Perforation/Dissection | Studies | 3 | 0 | 2 | 3 | 1 | 2 | 1 | 0 | 4 | 2 | 0 | 0 | 1 | 0 | 0
Reported Adverse Events | Perforation/Dissection | Patients | 190 | 0 | 17 | 157 | 15 | 14 | 7 | 0 | 21 | 49 | 0 | 0 | 34 | 0 | 0
Reported Adverse Events
Reported Adverse Events | Thrombus Formation | Studies | 2 | 0 | 5 | 3 | 1 | 1 | 2 | 0 | 3
Reported Adverse Events | Thrombus Formation | Patients | 165 | 0 | 20 | 157 | 15 | 4 | 12 | 0 | 9
Reported Adverse Events
Reported Adverse Events | Other Hemorrhage | Studies | 2 | 0 | 4 | 1 | 1 | 0 | 0 | 0 | 3
Reported Adverse Events | Other Hemorrhage | Patients | 166 | 0 | 25 | 20 | 15 | 0 | 0 | 0 | 13

Darker shading represents more frequent evaluation or larger number of patient evaluated

AICH=asymptomatic intracerebral hemorrhage; C=case report/case series; n=the total number of patients evaluated for any effectiveness or safety endpoint; P=prospective; R=retrospective; SICH=symptomatic intracerebral hemorrhage

Identified ongoing studies appear to be collecting data on adverse event endpoints similar to those assessed in completed studies.

## Key Question 3 What are the variables associated with use of the devices that may impact outcomes (e.g. time to deployment, training/expertise of interventionalist, location of infarct, concurrent therapies)?

Results of univariate and multivariate analyses reported in identified prospective and retrospective studies were used to answer Key Question 3. The effects of predictor variables reported by authors of studies on select outcomes (effectiveness and adverse events) are summarized in Table 15.^15,43,46,47,65–67^ Predictors are classified as to whether they were found to have beneficial (and statistically significant), harmful (and statistically significant) or indeterminate (not statistically significant regardless of effect direction) effects on outcomes. It is important to note that because these predictors were derived from single-arm (uncontrolled) studies, similar relationships may have been observed in these patients even if they were not treated with a neurothrombectomy device (that is to say, similar predictors are likely to be identified in a similar patient population not receiving neurothrombectomy devices).

Table 15 Effect of various variables on post-neurothrombectomy device outcomes

| Clinical Outcomes
Predictor Variables | Recanalization | NIHSS Improvement | Hemorrhage^*^ | mRS≤ 2 | Death
Recanalization∞43,46,59 | - | B | - | B | B
Older Age43,46 | - | - | - | H | H
Higher SBP43,46 | - | H | - | H | H
Higher Baseline NIHSS43,46,59 | I | - | - | H | H
ICA Occlusion Site (vs. mostly MCA)43,47,59 | I | - | - | I | H
Abnormal Hemostasis # 15 | I | - | I | H | I
Prior IV rtPA 47 | I | - | I | I | I
Concomitant IA thrombolytics47,60 | B | - | I | I | I
Prior Stroke 59 | - | - | - | - | H
Longer Procedure Duration46,59 | - | - | - | H | I
Right Brain Infarct 46 | - | - | - | H | -

B=beneficial; H=harmful; I=indeterminate (no statistically significant effect); IA=intra-arterial; ICA=internal carotid artery; IV rtPA=intravenous recombinant tissue plasminogen activator; MCA=middle cerebral artery; mRS=modified Rankin Scale; NIHSS=National Institutes of Health Stroke Scale; SBP=systolic blood pressure

* including symptomatic and asymptomatic hemorrhage

# INR>1.7, PTT>45 and/or platelet count <100,000

∞ Revascularization as defined by achieving TIMI 2–3 flow at the site of primary occlusion.

Evaluated predictors of outcome (Table 15) in these patients treated with a neurothrombectomy device include demographic, co-morbid disease, stroke severity and stroke treatment variables. These predictors were evaluated in studies (or pooled analyses) of the MERCI clot retriever and the Penumbra System. In addition to the variables listed in Table 15, researchers have suggested that the presence of collateral circulation, lesion volume and cerebral perfusion pressure have also been linked to outcomes in acute ischemic stroke patients.64 Of particular note, recanalization was the only variable that was found to be predictive of clinical benefit (achieving a mRS≤2) as well as lower mortality. These results are similar to those found in an earlier meta-analysis22 as well as a pooled analysis of the IMS I and II trials were reduced -dose IV followed by IA thrombolysis was associated with good outcomes.19

In a meta-analysis by Stead and colleagues published in 2008 evaluating available data on neurothrombectomy devices at that time, younger age and lower NIHSS score at presentation had beneficial effects on achieving a mRS≤2 (p=0.001).45 Conversely, patients with posterior circulation occlusions were found to have higher odds of 90-day mortality compared to those with anterior occlusions (either internal carotid or middle cerebral arteries). No other outcomes were affected by occlusion location. Time to mechanical intervention/deployment and concurrent thrombolytic administration was not associated with either mortality or attainment of mRS≤2.

No studies provided data assessing the relationship between the training of interventionalists and outcomes in patients treated with neurothrombectomy devices. However, studies of emerging technologies over the past 20 years have suggested that inadequate physician training and experience can adversely affect clinical outcomes.68

To date, two reports have been published by various neuroscience societies discussing training requirements for endovascular ischemic stroke interventions. Each report will be discussed individually in detail below.

The first is a report written and approved by multiple neuroscience societies (including the Society of NeuroInterventional Surgery; American Academy of Neurology; American Association of Neurological Surgeons, Cerebrovascular Section; and Society of Vascular & Interventional Neurology) representing practitioners involved in the medical, surgical, and endovascular care of patients with acute stroke.68 In regards to neurothrombectomy devices, they suggest the operator: (1) Completes an accredited [Accreditation Council for Graduate Medical Education (ACGME)] residency program which includes at least six months of documented cerebrovascular training, training in the diagnosis and management of acute stroke, and the interpretation of cerebral arteriography and brain imaging under the supervision of a board-certified neurologist, neurosurgeon, or neuroradiologist with the American Board of Medical Speciality (ABMS) eligibility or certification during a 4-year residency program. (2) Completes one year of graduate medical education in endovascular surgical neuroradiology. An ACGME-approved program is preferred but not required. (3) Have documented prior training and experience in catheter arteriography, including 100 cerebral arteriograms. Clinical outcomes must meet or exceed the American College of Radiology (ACR) benchmarks for technical success and complications. (4) Have documented prior training and experience in intracranial microcatheter (3-French) and microguidewire (0.014 inch) navigation under the supervision of fellowship-trained and credentialed neurointerventionalist(s). (5) Have documented prior experience in assessment and performance of endovascular stroke interventional procedures as the primary operator in 10 patients under the supervision of fellowship-trained and credentialed neurointerventionalists(s). (6) Previously credentialed physicians who perform IA catheter-directed stroke procedures at their local institutions should have documented procedural and clinical outcomes that meet national standards and published evidence-based guidelines. (7) Successfully complete a training course for use of any specific device.

The Society of Interventional Radiology (SIR) has devised training guidelines which includes both physician and facility requirements.69 These guidelines are broken up into five categories: (1) cognitive qualifications in neuroanatomy, pathophysiology, hemodynamics, and clinical correlations for ischemic and hemorrhagic stroke; (2) technical qualifications for catheter-directed pharmacologic stroke therapy; (3) technical qualifications for use of intracranial mechanical devices for stroke therapy; (4) preexisting credentials; and (5) maintenance of qualifications. At the time of the writing of these guidelines, the authors stated that intracranial mechanical devices had not been shown to improve clinical outcomes in stroke patients. Thus, definitive training requirements for these devices were not given. They do, however, acknowledge that physicians should meet the training criteria for pharmacologic lysis in ischemic strokes as well as successful completion of a training course for a specific neurothrombectomy device.

These training standard documents, although congruent in their aim, scope, and core requirements, differ in a notable way. The multi-society report by Meyers and colleagues recommends that individuals complete a 1-year endovascular surgical neuroradiology fellowship to successfully use neurothrombectomy devices.68 Alternatively, the SIR guidelines by Connors and colleagues refute this claim stating that this level of training is not necessary for those wishing to endovascularly treat acute ischemic stroke patients.69 They suggest that the requisite technical skills can be acquired through alternative advanced training and surrogate experience.