# References

1 Lopez AD, Mathers CD, Ezzati M, et al. Global and regional burden of disease and risk factors, 2001: systematic analysis of population health data. Lancet. 2006;367:1747-1757. [pmid: 16731270].
2 Lloyd-Jones D, Adams R, Carnethon M, et al. Heart disease and stroke statistics 2009 update: a report from the American Heart Association statistics committee and stroke statistics subcommittee. Circulation. 2009;119:480-486. [pmid: 19171871].
3 Broderick MD, William M. Feinberg lecture: stroke therapy in the year 2025: burden, breakthroughs, and barriers to progress. Stroke. 2004;35:205-211. [pmid: 14671248].
4 Lisabeth LD, Ireland JK, Risser JM, et al. Stroke risk after transient ischemic attack in a population-based setting. Stroke. 2004;35:1842-1846. [pmid: 15192239].
5 Heron MP, Hoyert DL, Xu J, et al. Preliminary Data for 2006. Hyattsvile, MD. National Center for Health Statistics. National Vital Statistics Report. 2008;56(16).
6 National Center for Health Statistics. Centers for Disease Control and Prevention. Compressed Mortality File: Underlying Cause of Death, 1979–2005. Atlanta, GA. Centers for Disease Control and Prevention. 2008. Available at: http://wonder.cdc.gov/mortSQL.html. Accessed September 22, 2009.
7 Centers for Disease Control and Prevention. Prevalence of disabilities and associated health conditions among adults: United States. 1999. MMWR Morb Mortal Wkly Rep. 2001;50:120-125. [pmid: 11393491].
8 Centers for Disease Control and Prevention. Outpatient rehabilitation among stroke survivors: 21 stats and the District of Columbia. MMWR Morb Mortal Wkly Rep. 2007;56:504-507. [pmid: 17522589].
9 Taylor TN, Davis PH, Torner JC, et al. Lifetime costs of stroke in the United States. Stroke. 1996;27:1459-1466. [pmid: 8784113].
10 Samsa GP, Matchar DB, Golstein L, et al. Utilities for major stroke: results from a survey of preferences among persons at increased risk for stroke. Am Heart J. 1998;136:703-713. [pmid: 9778075].
11 McCullagh E, Brigstocke G, Donaldson N, et al. Determinants of caregiving burden and quality of life in caregivers of stroke patients. Stroke. 2005;36:2181-2186. [pmid: 16151029].
12 Rigby H, Gubitz G, Eskes G, et al. Caring for stroke survivors: baseline and 1-year determinants of caregiver burden. Int J Stroke. 2009;4:152-158. [pmid: 19659814].
13 Carod-Artal FJ, Ferreira Coral L, Trizotto DS, et al. Burden and perceived health status among caregivers of stroke patients. Cerebrovasc Dis. 2009;28:475-480.
14 Fischer U, Arnold M, Nedeltchev K, et al. NIHSS score and arteriographic findings in acute ischemic stroke. Stroke. 2005;36:2121-2125. [pmid: 16151026].
15 Nogueira RG, Lielbeskind DS, Sung G, et al. MERCI Multi MERCI Writing Comm. Predictors of clinical outcomes in acute ischemic stroke patients undergoing thrombectomy: Pooled analysis of the MERCI and multi MERCI trials. Stroke. 2009;40:3777-3783. [pmid: 19875740].
16 Smith WS, Lev MH, English JD, et al. Significance of large vessel intracranial occlusion causing acute ischemic stroke and TIA. Stroke. 2009;40:3834-3840. [pmid: 19834014].
17 Smith WS, Tsao JW, Billings ME, et al. Prognostic significance of angiographically confirmed large vessel intracranial occlusion in patients presenting with acute brain ischemia. Neurocrit Care. 2006;4:14-17. [pmid: 16498189].
18 Josephson SA, Saver JL, Smith WS, Merci and Multi Merci Investigators. Comparison of mechanical embolectomy and intraarterial thrombolysis in acute ischemic stroke within the MCA: MERCI and Multi MERCI compared to PROACT II. Neurocrit Care. 2009;10:43-49. [pmid: 19030784].
19 Tomsick T, Broderick J, Carrozella J, et al. Revascularization results in the interventional management of stroke II trial. AJNR Am J Neuroradiol. 2008;29:582-587. [pmid: 18337393].
20 Dirnagl U, Iadecola C, Moskowitz MA. Pathobiology of ischaemic stroke: an integrated view. Trends Neurosci. 1999;22:391-397. [pmid: 10441299].
21 Albers GW, Amarenco P, Easton, et al. Antithrombotic and thrombolytic therapy for ischemic stroke. Chest. 2008;133:630S-669S. [pmid: 18574275].
22 Rha JH, Saver JL. The impact of recanalization on ischemic stroke outcome: a meta-analysis. Stroke. 2007;38:967-973. [pmid: 17272772].
23 Khatri P, Abruzzo T, Yeatts SD, et al. Good clinical outcome after ischemic stroke with successful revascularization is time-dependent. Neurology. 2009;73:1066-1072. [pmid: 19786699].
24 Lyden PD, editor. Thrombolytic Therapy for Acute Stroke. 2nd ed. Springer-Verlag. New York, NY. 2005.
25 NINDS rt-PA Stroke Study Group. Tissue plasminogen activator for acute ischemic stroke. N Engl J Med. 1995;333:1581-1587. [pmid: 7477192].
26 The ATLANTIS, ECASS, and NINDS rt-PA Study Group Investigators. Association of outcome with early stroke treatment: pooled analysis of ATLANTIS, ECASS, and NINDS rt-PA stroke trials. Lancet. 2004;363:768-774. [pmid: 15016487].
27 Hacke W, Kaste M, Bluhmki E, et al. Thrombolysis with alteplase 3 to 4.5 hours after acute ischemic stroke. N Engl J Med. 2008;359:1317-1329. [pmid: 18815396].
28 Wahlgren N, Ahmed N, Davalos A, et al. for the SITS-MOST Investigators. Thrombolysis with alteplase for acute ischaemic stroke in the Safe Implementation of Thrombolysis in Stroke—Monitoring Study (SITS-MOST): an observational study. Lancet. 2007;369:275-282. [pmid: 17258667].
29 Wahlgren N, Ahmed N, Davalos A, et al. for the SITS Investigators. Thrombolysis with alteplase 3–4.5 h after acute ischaemic stroke (SITS-ISTR): an observational study. Lancet. 2008;372:1303-1309. [pmid: 18790527].
30 del Zoppo GJ, Saver JL, Jauch EC, et al. Expansion of the time window for treatment of acute ischemic stroke with intravenous tissue plasminogen activator: a science advisory from the American Heart Association/American Stroke Association. Stroke. 2009;40:2945-2948. [pmid: 19478221].
31 Zangerle A, Kiechl S, Spiegel M, et al. Recanalization after thrombolysis in stroke patients: predictors and prognostic implications. Neurology. 2007;68:39-44. [pmid: 17200490].
32 Wolpert SM, Bruckmann H, Greenlee R, et al. Neuroradiologic evaluation of patients with acute stroke treated with recombinant tissue plasminogen activator. Am J Neuroradiol. 1993;14:3-13. [pmid: 8427107].
33 Alexandrov AC, Grotta JC. Arterial reocclusion in stroke patients treated with intravenous tissue plasminogen activator. Neurology. 2002;59:862-867. [pmid: 12297567].
34 Brott T, Bogousslavsky J. Treatment of acute ischemic stroke. N Engl J Med. 2000;343(10):710-722. [pmid: 10974136].
35 Furlan A, Higashida R, Wechsler L, et al. Intra-arterial prourokinase for acute ischemic stroke. The PROACT II study: a randomized controlled trial. Prolyse in acute cerebral thromboembolism. JAMA. 1999;282:2003-2011. [pmid: 10591382].
36 Ciccone A, Valvassori L, Ponzio M, et al. Intra-arterial or intravenous thrombolysis for acute ischemic stroke? The SYNTHESIS pilot trial. J Neurointervent Surg. 2010;2:74-79.
37 Guidance for Industry and FDA Staff: Pre-Clinical and Clinical Studies for Neurothrombectomy Devices. U.S. Department of Health and Human Services, Food and Drug Administration, Center for Devices and Radiological Health. Document issued on June 18, 2007. Available at: http://www.fda.gov/MedicalDevices/DeviceRegulationandGuidance/GuidanceDocuments/ucm071403.htm. Accessed December 21, 2009.
38 Thomassen L, Bakke SJ. Endovascular reperfusion therapy in acute ischaemic stroke. Acta Neurol Scand. 2007;115(Suppl 187):22-29.
39 Becker KJ, Brott TG. Approval of the MERCI Clot Retriever: a critical review. Stroke. 2005;36:400-403. [pmid: 15653576].
40 Nogueira RG, Schwamm LH, Hirsch JA. Endovascular approaches to acute stroke, part 1: drugs, devices, and data. Am J Neuroradiol. 2009;30:649-661. [pmid: 19279271].
41 Lutsep HL. Mechanical endovascular recanalization therapies. Curr Opin Neurol. 2008;21:70-75. [pmid: 18180654].
42 United States Food and Drug Administration. 510(k) Premarket Notification. Available at: http://www.accessdata.fda.gov/scrIpts/cdrh/cfdocs/cfPMN/pmn.cfm. Accessed December 21, 2009.
43 Safety and efficacy of endovascular thrombectomy in patients with abnormal hemostasis pooled analysis of the MERCI and multi MERCI trials. Stroke. 2009;40:516-522. [pmid: 19095994].
44 Gupta R. Arterial vasospasm during mechanical thrombectomy for acute stroke. J Neuroimaging. 2009;19:61-64. [pmid: 18801002].
45 Stead LG, Gilmore RM, Bellolio MF, et al. Percutaneous clot removal devices in acute ischemic stroke: a systematic review and meta-analysis. Arch Neurol. 2008;65:1024-1030. [pmid: 18695052].
46 Smith WS, Sung G, Starkman S, et al. Safety and efficacy of mechanical embolectomy in acute ischemic stroke: Results of the MERCI trial. Stroke. 2005;36:1432-1438. [pmid: 15961709].
47 Smith WS, Sung G, Saver J, et al. Mechanical thrombectomy for acute ischemic stroke: final results of the Multi MERCI trial. Stroke. 2008;39:1205-1212. [pmid: 18309168].
48 Nichols C, Carrozella J, Yeatts S, et al. Is periprocedural sedation during acute stroke therapy associated with poorer functional outcomes?. J Neurointervent Surg. 2010;2:67-70.
49 The Merci Retrieval System.^®^. Available at: http://www.concentric-medical.com/webpage.php?ln_id=53. Accessed December 21, 2009.
50 Velat GJ, Hoh BL, Levy EI, et al. Primary intracranial stenting in acute ischemic stroke. Curr Cardiol Rep. 2010;12:14-9. [pmid: 20425179].
51 Mocco J, Hanel RA, Sharma J, et al. Use of a vascular reconstruction device to salvage acute ischemic occlusions refractory to traditional endovascular recanalization methods. J Neurosurg. 2010;112:557-562. [pmid: 19764826].
52 Zaidat OO, Wolfe T, Hussain SI, et al. Interventional acute ischemic stroke therapy with incracranial self-expanding stent. Stroke. 2008;39:2392-2395. [pmid: 18556584].
53 Levy EI, Mehta R, Gupta R, et al. Self-expanding stents for recanalization of acute cerebrovascular occlusions. AJNR Am J Neuroradiol. 2007;28:816-822. [pmid: 17494649].
54 Brekenfeld C, Schroth G, Mattle HP, et al. Stent placement in acute cerebral artery occlusion. Use of a self-expandable intracranial stent for acute stroke treatment. Stroke. 2009;40:847-852. [pmid: 19182080].
55 Levy EI, Siddiqui AH, Crumlish A, et al. First Food and Drug Administration-approved prospective trial of primary intracranial stenting for acute stroke. SARIS (Stent-Assisted Recanalization in acute Ischemic Stroke). Stroke. 2009;40:3552-3556. [pmid: 19696415].
56 Kelly ME, Furlan AJ, Fiorella D. Recanalization of an acute middle cerebral artery occlusion using a self-expanding, reconstrainable, intracranial microstent as a temporary endovascular bypass. Stroke. 2008;39:1770-1773. [pmid: 18388338].
57 Suh SH, Lee KY, Hong CK, et al. Temporary stenting and retrieval of the self-expandable, intracranial stent in acute middle cerebral artery occlusion. Neuroradiology. 2008;51:541-544. [pmid: 19424689].
58 Hauck EF, Mocco J, Snyder KV, et al. Temprary endovascular bypass: a novel treatment for acute stroke. Am J Neuroradiol. 2009;30:1532-1533. [pmid: 19279279].
59 Castano C, Serena J, Davalos A. Use of the new Solitaire™ AB device for mechanical thrombectomy when Merci clot retriever has failed to remove the clot. A case report. Intervent Neuroradiol. 2009;15:209-214.
60 Henkes H, Liebig T, Miloslavski E, et al. Endovascular acute ischemic stroke treatment using the self-expanding and fully retrievable Solitaire stent. Stroke. 2009;40:E247-248. Abstract P410.
61 Castano C, Dorado L, Guerrero C, et al. Mechanical thrombectomy with the Solitaire AB device in large artery occlusions of the anterior circulation. A pilot study. Stroke. 2010. 06. 10. Epub ahead of print.
62 Liebig T, Reinartz J, Hannes R, et al. Comparative in vitro study of five mechanical embolectomy systems: effectiveness of clot removal and risk of distal embolization. Neuroradiology. 2008;50:43-52. [pmid: 17932666].
63 Gralla J, Schroth G, Remonda L, et al. Mechanical thrombectomy for acute ischemic stroke: thrombus-device interaction, efficiency, and complications in vivo. Stroke. 2006;37:3019-3024. [pmid: 17053185].
64 Nogueira RG, Yoo AJ, Buonanno FS, et al. Endovascular approaches to acute stroke, part 2: a comprehensive review of studies and trials. AJNR Am J Neuroradiol. 2009;30:859-875. [pmid: 19386727].
65 PPST Investigators. The penumbra pivotal stroke trial: Safety and effectiveness of a new generation of mechanical devices for clot removal in intracranial large vessel occlusive disease. Stroke. 2009;40:2761-2768. [pmid: 19590057].
66 Lin R, Vora N, Zaidi S, et al. Mechanical approaches combined with intra-arterial pharmacological therapy are associated with higher recanalization rates than either intervention alone in revascularization of acute carotid terminus occlusion. Stroke. 2009;40:2092-2097. [pmid: 19390066].
67 Patil CG, Long EF, Lansberg MG. Cost-effectiveness analysis of mechanical thrombectomy in acute ischemic stroke. J Neurosurg. 2009;110:508-513. [pmid: 19025358].
68 Meyers PM, Schumacher HC, Alexander MJ, et al. Performance and training standards for endovascular ischemic stroke treatment. J Neurosurg. 2010;113:149-152. [pmid: 20035576].
69 Connors JJ, Sacks D, Black CM, et al. Training guidelines for intra-arterial catheter-directed treatment of acute ischemic stroke: a statement from the special writing group of the Society of Interventional Radiology. J Vasc Interv Radiol. 2009;20:1507-1522. [pmid: 19944980].
70 Khatri P, Hill MD, Palesch YY, et al. Methodology of the International Management of Stroke III Trial. Int J Stroke. 2008;3:130-137. [pmid: 18706007].
71 Mauldin PD, Simpson KN, Palesch YY, et al. Design of the economic evaluation for the International Management of Stroke (III) trial. Int J Stroke. 2008;3:138-144. [pmid: 18706008].