# Methods

## Key Terminology and Definitions

Anterior Circulation: The blood flow provided by the two internal carotid arteries, which terminate as the anterior and middle cerebral arteries.
Barthel Index (BI): A scale used to measure performance in basic activities of daily living (ADL). It uses ten variables describing ADLs and mobility. A higher number is associated with a greater likelihood of being able to live at home with a degree of independence following discharge from hospital.
Basilar Artery (BA): Artery that arises from the confluence of the two vertebral arteries at the junction between the medulla oblongata and the pons. It is one of the arteries that supply the brain with oxygen-rich blood.
Glasgow Outcome Scale (GOS): The Glasgow Outcome Scale is a 5-point score given to victims of traumatic brain injury at some point in their recovery. It is a very general assessment of the general functioning of the person who suffered a head injury. In general, this scale is not used in the clinical management of the patient. Rather, it is used often in research to quantify the level of recovery patients have achieved.
Internal Carotid Artery (ICA): Main artery of the head and neck that helps supply blood to the brain.
Middle Cerebral Artery (MCA): One of the three major arteries that supplies blood to the cerebrum. It arises from the internal carotid and continues into the lateral sulcus where it branches and projects to many of the lateral cerebral cortex. It also supplies blood to the anterior temporal lobes and the insular cortices.
modified Rankin Scale (mRS): A commonly used scale for measuring the degree of disability or dependence in the daily activities of people who have suffered a stroke. It has become the most widely used clinical outcome measure for stroke clinical trials. The scale runs from 0 (perfect health without symptoms) to 6 (death).
National Institutes of Health Stroke Scale (NIHSS): A method developed by the National Institutes of Health to gauge the severity of stroke. The NIHSS is a 15-item neurologic examination stroke scale used to evaluate the effect of acute cerebral infarction on the levels of consciousness, language, neglect, visual-field loss, extraocular movement, motor strength, ataxia, dysarthria, and sensory loss.
Neurothrombectomy Device: A device intended to retrieve or destroy blood clots in the cerebral neurovasculature by mechanical, laser, ultrasound technologies, or combination of technologies.
Posterior Circulation: The blood flow provided by the two vertebral arteries, which join together as a single basilar artery.
Recanalization: The restoration of the lumen of a blood vessel following thrombotic occlusion by restoration of the channel or by the formation of new channels. Thrombolysis in Myocardial Infarction (TIMI) grade 2 represents partial recanalization. TIMI grade 3 represents complete recanalization. The TIMI grading scale was initially developed to assess coronary circulation.
Vertebral Arteries(VA): Branches of the subclavian arteries.

## Criteria for Inclusion/Exclusion of Studies in the Review

We developed a list of neurothrombectomy devices based on the FDA’s guidance definition of a neurothrombectomy device,37 published literature, and a search of the FDA CDRH’s database to identify neurothrombectomy devices that have received FDA approval (510(k) documents).42

Two investigators independently screened citations at the abstract level to identify potentially relevant studies, case series or case reports. Throughout this technical brief, our use of the terminology ‘studies’ will refer only to prospective, single-arm studies or retrospective studies enrolling consecutive patients. The terminology ‘reports’ will refer to the latter studies in addition to case series and case reports. All potentially eligible citations were retrieved for full-text review and examined for eligibility. We included human studies of any design or case series or case reports, as long as they included patients with an acute ischemic stroke, and reported data on at least one clinical effectiveness outcome (e.g., recanalization, mortality, mRS, or outcome score including NIHSS, Barthel Index or GOS) or harm [e.g., failure to deploy the device or remove the clot, device breakage/fracture, perforation, dissection, thrombus formation proximal, adjacent, or distal to the clotsite, vasospasm or hemorrhage (intracerebral and other)]. No language restrictions were used in the searching for reports; however, only reports in English were included in our qualitative review of the literature.

## Searching for the Evidence: Literature Search Strategies for Identification of Relevant Studies To Answer the Key Questions

Two independent investigators conducted systematic literature searches of MEDLINE, the Cochrane Central Register of Controlled Trials, SCOPUS and Web of Science as well as the Cochrane Database of Systematic Reviews, from the earliest possible date until May 2010. No language restrictions were imposed during the literature identification stage. In addition, a manual search of references from identified reports or review articles was conducted. Search strategies used for MEDLINE and the Cochrane Central Register of Controlled Trials are included in Appendix A. Searches of Scopus and Web of Science used similar terminology. After verifying products in current clinical practice and those in development, we asked the Scientific Resource Center (SRC) at the Oregon Evidence-based Practice Center to contact the different manufacturers to obtain scientific information packets (Penumbra Inc. and EKOS Inc. were the only two manufacturers to provide information). (Appendix B) Finally, we conducted a grey literature search utilizing Google and specific search terms.

## Data Abstraction and Data Management

Through the use of a standardized data abstraction tool, two reviewers independently collected data, with disagreement resolved by a third reviewer. The following information was obtained from each report, where applicable: author identification, year of publication, study design characteristics (prospective single arm study, retrospective study, randomized controlled trial, nonrandomized comparative study, case series or reports), study population (including study inclusion and exclusion criteria, duration of patient follow-up), patient baseline characteristics (age, gender), disease severity (baseline NIHSS, baseline TIMI flow), location of occluded artery (anterior, posterior, other), time from symptom onset to device deployment or angiography, use of concurrent standard medical therapies (including prior or concurrent use of IV/IA thrombolysis, angioplasty, stents), whether outcomes assessment was blinded, and the device used. Effectiveness outcomes included: recanalization as measured by post-TIMI flow grade (0/1=no recanalization, 2=partial recanalization, 3=complete recanalization) or similar methodology, mortality, mRS (≤2=good outcome, ≥3=poor outcome), NIHSS score (including the ≥ 4 points decrease deemed significant by the FDA),37 Barthel Index and GOS. Harms assessed included: failure to deploy the device or remove the clot (technical success), device breakage/fracture, perforation, dissection, thrombus formation proximal, adjacent, or distal to the clot site, vasospasm, or hemorrhage (including symptomatic and asymptomatic intracerebral and subarachnoid hemorrhage from vessel injury and other bleeding).

Variables associated with the use of devices that may impact outcomes were identified a prior with input from our clinical experts and approved as part of the initial protocol. We evaluated each prospective or retrospective study (excluding case reports and case series) for all independent predictors of response. Data from multivariable analyses was preferentially used over univariate analyses when available. Each variable was classified as having either a beneficial (p<0.05 for improving the outcome), harmful (p<0.05 for worsening the outcome) or indeterminate (no statistically significant change regardless of direction of effect).

## Assessment of Methodological Quality of Individual Studies

We assessed the study design and classified it as a prospective, single -arm study, retrospective study enrolling consecutive patients, or a case series or case report. For prospective, single-arm and retrospective studies enrolling consecutive patients, we collected data on whether outcome assessment was blinded.

## Data Synthesis

We utilized in-depth tables summarizing what is known about the relevant studies and case series or case reports. We created study density figures to summarize the totality of information available on the effectiveness and safety of the devices in this technical brief. No formal quantitative synthesis (meta-analysis) was undertaken.

## Grading the Evidence for Each Key Question

This was deemed not applicable for this technical brief.

## Future Research/Research Gaps

We searched http://www.clinicaltrials.gov/ to identify ongoing trials. Upon completion of the literature scan portion of this technical brief, we highlight areas where we feel further research is justified.