# Discussion

The natural history and poorclinical outcomes seen in patients with acute ischemic strokes has been well documented.15–19 The advent of neurothrombectomy devices as a method of providing adequate recanalization in these patients has created a new option for the management of these patients. The clinical utility of these technologies particularly intriguing given the data showing significantly improved outcomes with successful recanalization of an occluded cerebral vessel.22 Most especially hopeful are the data showing the strongest benefits with those achieving recanalization as early as possible.23 Substantial infrastructure developed in the years since the clearance of these devices support the shifts in acute ischemic stroke care, which were prompted by these endovascular advances. However, a paucity of high quality research evaluating neurothrombectomy devices exists. Currently, only two neurothrombectomy devices, the MERCI clot retriever and Penumbra System, are FDA-cleared to treat patients with acute ischemic stroke, with a plethora of other neurothrombectomy devices studied in an off-label capacity. A strong majority of available data lies with the two cleared devices, but the comparative effectiveness of these devices remains unstudied.

Little data exist regarding the current usage of such devices. Data from Concentric Medical suggests that >10,000 patients have been treated with the MERCI clot retriever.49 The extent of usage of other neurothrombectomy devices in the “real-world” setting is unknown.

Our literature scan failed to identify any direct human comparative studies of neurothrombectomy devices, either to IV rtPA or each other. Instead, investigators frequently studied devices as part of prospective single-arm studies, non-comparative retrospective studies enrolling consecutive patients, or case series or case reports. Based upon the expected paucity of comparative data, this report was assigned to be a technical brief by AHRQ. Consequently, our main objective was to describe neurothrombectomy devices currently being used or actively investigated in the treatment of patients with acute ischemic stroke and to summarize the evidence supporting their use, not to draw conclusions regarding the effectiveness or safety compared to each other or the chief medical intervention, IV rtPA, or this drug delivered via an endovascular approach, IA rtPA.

A previous systematic review of neurothrombectomy devices by Stead and colleagues was identified during our literature scan.45 Similar to our technical brief, this systematic review identified and qualitatively synthesized only non-comparative studies and case series and reports. However, the literature search on which their review was based extended only through March 2006, and consequently did not include the majority of the highest quality data on neurothrombectomy devices (including that of the MERCI and Penumbra Systems). Thus our technical brief should represent the most up-to-date review of the literature at this time. Unlike our review, Stead and colleagues quantitatively compared pooled device results to a control group derived from their own institution’s stroke population. They found that when compared with a similar matched cohort, the neurothrombectomy patients had good functional recovery (mRS≤2) in 34.5 percent of patients compared with 10.7 percent of patients matched for age, sex, and NIHSS score, suggesting the neurothrombectomy group was nearly 15 times more likely to have good functional recovery compared with the control group. While, perhaps the best “controlled” data available to date, this analysis is fraught with limitations, including the fact that the neurothrombectomy cohort was not homogeneous, as the comparison was to a single-center historically concurrent cohort (albeit matched for important variables), and individuals were not randomly allocated to treatment, thus allowing the influence of confounding variables.

A continuing area of uncertainty revolved around the patient population most likely to benefit from use of neurothrombectomy devices. Indeed, many previously published studies evaluating devices that are FDA-cleared enrolled patients who presented within 8 hours of ischemic stroke symptom onset, had high baseline NIHSS scores, and had either failed or were ineligible to receive IV rtPA.15–19,65 In addition, many of the patients enrolled in these trials had occlusions of the large intracranial vessels which have been demonstrated to respond poorly to IV rtPA therapy.32–33 Ongoing clinical trials are evaluating the utility of various imaging techniques to better identify which patients are most likely to benefit from neurothrombectomy device use. This emerging data should help guide clinicians in choosing the most appropriate treatment of acute ischemic strokes, although further research is warranted.

## Future Research/Research Gaps

Since the literature generated to evaluate neurothrombectomy devices in acute ischemic stroke are still in their infancy, identifying gaps in current knowledge and guiding future research efforts is paramount. The general goal of future trials should be to identify appropriate patients who could most benefit from neurothrombectomy treatment and improve their chance of good functional recovery.

Currently, there are eleven on-going studies evaluating at least one neurothrombectomy device in acute ischemic stroke listed on the http://www.clinicaltrials.gov/ Web site or mentioned in previous review articles (Table 3).64 The first of these eleven studies is estimated to end sometime in 2010. All appear to be enrolling patients based upon inclusion and exclusion criteria that are similar to those already used by the prospective and retrospective studies detailed throughout this report. One exception is the Mechanical Retrieval and Recanalization of Stroke Clots Using Embolectomy (MR RESCUE) trial which will allow patients to receive IV rtPA up to 4.5 hours after symptom onset. Seven of these studies have randomized, controlled designs with projected enrollment ranging from 20–900. The other four studies have prospective, observational designs ranging from 200–2000 projected participants. Six of the seven randomized controlled trials are allowing the use of multiple neurothrombectomy devices; most compare the use of neurothrombectomy devices to best medical therapy (with or without IV rtPA). Both the MERCI clot retriever and the Penumbra System have prospective observational studies in progress. Compared to previous studies of these agents of similar design, these studies will enroll much larger sample sizes (n=2,000 and 3,000, respectively).

Our literature scan did not identify any reports of neurothrombectomy devices evaluating their impact on health-related quality-of-life (HRQoL). We identified only one previous economic evaluation of neurothrombectomy devices: a Markov model that evaluated the cost and effectiveness of mechanical thrombectomy compared with standard medical therapy in patients who were ineligible to receive intravenous rtPA.67 The ongoing Interventional Management of Stroke (IMS) III trial, which is designed to evaluate whether combination use of intravenous and IA strategies (including use of the MERCI or EKOS device) vs. intravenous rtPA alone, is planned to measure both HRQoL and pharmacoeconomic outcomes.70,71

The use of advanced imaging techniques should be incorporated into future randomized, controlled trials to aid in identifying those patients most likely to benefit from neurothrombectomy devices as well as the performance of these devices at varying levels of occlusion. In fact, a number of on-going trials are currently studying the utilization of advanced imaging techniques in acute ischemic stroke management (Table 3). The MR RESCUE trial is using multimodal CT and MRI imaging to aid in identification of patients most likely to benefit from device use. The Penumbra Imaging Collaborative Study (PICS) is using “real world” data to determine if there is a correlation between the imaging-defined size of the ischemic penumbra at hospital admission and patient outcomes in acute ischemic stroke patients who received the Penumbra System. The Imaging Guided Patient Selection for Interventional Revascularization Therapy (START) trial is enrolling acute ischemic stroke patients with a known imaging-defined infarct volume to evaluate the impact of the Penumbra System on functional and angiographic outcomes.

The utility of studies determining the comparative effectiveness of neurothrombectomy devices and IV rtPA in patients reporting within a 3-hour window from time of stroke onset and having no contraindications to either therapy has been questioned by some. This is based on the fundamentally different patient populations at which these treatments are targeted. This further emphasizes the need for improved patient selection based on the results of neuroimaging techniques. In addition, for those patients with contraindications or who are refractory to IV rtPA, it is unclear which device is the most efficacious or safe. The SWIFT trial will be the first study to prospectively examine the comparative effectiveness of two different neurothrombectomy devices, the SOLITAIRE FR and MERCI. Direct head-to-head trials clinical trials comparing various neurothrombectomy devices may be limited given the wide etiology and morphology of ischemic strokes.

It would seem reasonable to conduct studies to answer such research gaps using a randomized controlled trial design, powered to show equivalency or non-inferiority of devices. Future trials should focus on accepted efficacy and safety endpoints, but also consider collecting data on health-related quality-of-life. Additionally, studies focused on broadening the opportunity for patients admitted to outlying primary stroke centers to receive treatment at comprehensive centers with endovascular services are required.