# Background and Objectives for the Systematic Review

## Prevalence of Ischemic Stroke

Stroke is the third leading cause of death following diseases of the heart and cancer.1,2 A majority of strokes are classified as ischemic in nature (87 percent), with intracerebral hemorrhagic (10 percent) and subarachnoid hemorrhagic stroke (3 percent) accounting for the rest.2 Every year in the United States, approximately 795,000 people develop a new or recurrent stroke, with 610,000 first attacks and 185,000 recurrent attacks.2 The annual rate of strokes is expected to increase to 1.2 million cases by the year 2025, a troubling trend that underlines the urgency of adequate ischemic stroke treatment.3 Stroke occurs more commonly in females than males, especially at older ages.4 Blacks have a two -fold higher risk of first -ever stroke than Caucasians, with age-adjusted incidences of 6.6 per 1000 in black men as compared with 3.6 per 1000 in Caucasian men.4 In 2006, 43.6 deaths occurred due to stroke per 100,000 people in the Unites States, averaging out to one death due to stroke every 3 to 4 minutes. 2,5 In 2005, the overall mortality rate from stroke was approximately 44.7 per 100,000 for Caucasian males, 70.5 per 100,000 for black males, 44.0 per 100,000 for Caucasian females, and 60.7 per 100,000 for black females.6 Lower mortality rates were seen in Hispanic, Asian, and American Indian populations as compared with Caucasian populations.2

Stroke is the leading cause of long-term disability in the United States. Thirty percent of stroke survivors require outpatient rehabilitation services7,8 and 15 to 30 percent of patients remain permanently disabled.2 Costs associated with acute stroke were estimated to approach $68.9 billion in 2009, with inpatient hospital costs accounting for 70 percent of the total cost in the first year after stroke.2,9 Significant decreases in health -related quality-of-life are also seen following a stroke.2 Studies have shown that at -risk patients view the consequences of experiencing an ischemic stroke as being worse than death.10 Additionally, evidence has demonstrated the significant impact of ischemic stroke on caregiver burden and quality-of-life in caregivers.11–13

## Natural History of Ischemic Stroke

The poor overall outcome associated with acute ischemic stroke is well recognized. A number of patient variables have been identified as being related to worse outcomes, including advancing age and stroke severity.14,15 Fischer and colleagues demonstrated that a National Institutes of Health Stroke Score (NIHSS) of 10 or greater was predictive of angiographic findings consistent with a cerebrovascular occlusion.14 More recent data has suggested that a higher admission NIHSS score, as well as advancing age, are independent predictors of worse neurologic outcome following an acute ischemic stroke.15,16 Thus, early identification of patients at higher risk for poor outcome is essential to delivering effective treatment and improving long-term prognosis.

Acute ischemic stroke due to occlusions in large cerebral vessels are particularly troublesome. These ischemic events involve, but are not limited to, vertebral, basilar, and carotid terminus arteries as well as the anterior and middle cerebral arteries (MCA). Smith and colleagues reported that large vessel occlusions represented 46 percent of strokes and 13 percent of transient ischemic attacks (TIAs) in a cohort of 735 patients presenting within 24 hours of symptom onset.16 Indeed, large vessel occlusions were predictive of higher 6 -month mortality [Odds Ratio (OR) 4.5, 95 percent Confidence Interval (CI) 2.7 to 7.3; p<0.001].17 In addition, the likelihood of a good clinical outcome [as defined by a modified Rankin Scale (mRS) score ≥2] at 6 months was negatively predicted by the presence of a large vessel occlusion [OR 0.33, 95 percent CI 0.24 to 0.45; p<0.001]. Moreover, approximately half of patients with anterior circulation large vessel occlusions will die without revascularization and only approximately 10 percent will achieve good functional outcomes at 3 months.15,18,19

## Reperfusion Strategies for Treatment of Ischemic Stroke

The pathophysiologic basis for an acute ischemic stroke begins with the occlusion of an intracranial vessel either by an embolus or a local thrombus, reducing blood flow to the downstream brain region.20 If blood f low is not restored to the affected area, ischemia and eventual cell death will occur in a time-dependent fashion.20 Currently available treatment options for acute ischemic stroke focus on restoring cerebral perfusion to the affected area as quickly as possible thereby reducing or preventing brain infarction and minimizing long-term disability and stroke-related mortality.21 In a meta-analysis of 53 studies by Rha and Saver, successful recanalization of the occluded cerebral vessel is associated with lower 3 -month mortality (OR 0.24, 95 percent CI 0.16 to 0.35) and improved functional outcomes (OR 4.43, 95 percent CI 3.32 to 5.91) than those that are not recanalized.22 In more recent studies, final recanalization was the strongest predictor of clinical outcomes in patients being treated for acute ischemic stroke.15 Khatri and colleagues suggest that those achieving later angiographic reperfusion experience fewer clinical benefits than those that achieve it earlier.23

Some thrombolytic agents, including recombinant tissue plasminogen activator (alteplase, rtPA), restore cerebral perfusion by activating plasminogen at the site of the occlusion, subsequently dissolving the clot.24 Intravenous (IV) rtPA has been approved by the United States Food and Drug Administration (FDA) for the treatment of acute ischemic stroke and is currently indicated for use within the first 3 hours of onset of symptoms.21 The National Institutes of Neurological Disorders and Stroke (NINDS) rtPA Stroke Study Group conducted a randomized, double-blind trial evaluating the benefits of IV rtPA treatment (0.9 mg/kg) administered within 3 hours of ischemic stroke onset (n=624).25 At 3 -months, patients receiving IV rtPA had improved functional outcomes (mRS <1) vs. the group receiving placebo (39 percent vs. 29 percent; OR 1.7, 95 percent CI 1.2 to 2.6). In addition, four commonly utilized tools to assess stroke-related deficits and disabilities demonstrated superiority of IV rtPA as indicated by improvements in the Barthel Index (OR 1.6, 95 percent CI 1.1 to 2.5), mRS (OR 1.7, 95 percent CI 1.1 to 2.5), Glasgow Outcome Scale (GOS) (OR 1.6, 95 percent CI 1.1 to 2.5) and the NIHSS (OR 1.7, 95 percent CI 1.0 to 2.8).

Use of IV rtPA beyond the 3 hour timeframe has been limited. However, a pooled analysis of six randomized, placebo-controlled trials showed that patients who received IV rtPA between 3 and 4.5 hours after stroke onset were at an increased odds of a favorable outcome (a composite of stroke-related disabilities, severity of disabilities and abilities to conduct activities of daily living) as compared with placebo (OR 1.4, 95 percent CI 1.05 to 1.85).26 The subsequently published European Cooperative Acute Stroke Study (ECASS III), which was powered based on the aforementioned meta-analysis, showed that patients receiving IV rtPA between 3 to 4.5 hours after symptom onset had significantly higher odds of a more favorable outcome (52.4 percent vs. 45.2 percent; OR 1.34, 95 percent CI 1.02 to 1.76), with no differences in mortality (p=0.68) but higher incidence of ICH seen (p=0.001).27 In addition, two observational studies, the Safe Implementation of Thrombolysis in Stroke Monitoring Study (SITS-MOST)28 and the SITS -international stroke treatment registry (SITS-ISTR)29 confirmed the benefits of rtPA use at 3 to 4.5 hours after ischemic stroke. Based on these findings, the American Heart Association and American Stroke Association issued a scientific advisory in 2009 recommending the use of IV rtPA in eligible patients presenting within 3 to 4.5 hours after the onset of stroke symptoms. This was a Class I recommendation with B level of evidence for most patients but for those older than 80 years, taking oral anticoagulants, with a baseline NIHSS score greater than 25, or with both a history of stroke and diabetes, rtPA use within 3 to 4.5 hours was a Class IIb recommendation with C level of evidence.30

Despite appropriate IV rtPA use, rates of recanalization remain highly variable ranging from 30 to 92 percent during the initial 6 to 24 hours after treatment.31 Recanalization rates vary depending on the site of the occlusion: events in large cerebral vessels having particularly high clot burden may not adequately respond to IV rtPA. Early observations suggested that revascularization rates with IV rtPA ranged from 10 percent in internal cerebral artery (ICA) occlusions to less than 30 percent in MCA occlusions.32 Reocclusion rates of 34 percent have also been shown following IV rtPA therapy, further reducing the durability of pharmacologic monotherapy in these patients.33 In addition, delays in arriving in the emergency department and unavailability of IV rtPA in some centers make thrombolytic reperfusion therapy viable in less than five percent of patients with acute stroke.34 Thus, patients identified as having strokes less likely to respond to IV rtPA are in need of other methods for achieving recanalization, particularly those with large vessel occlusions.

The advent of catheter-based delivery of thrombolytic agents at the site of occlusion seemed an attractive alternative. Clinical trials evaluated the use of intra-arterial (IA) rtPA in patients presenting within 6 hours of symptom onset resulting from MCA occlusions.35 At 3 -months, patients who received IA rtPA achieved significantly higher clinical success (mRS ≥2) than those who received heparin control (40 percent vs. 25 percent; p=0.04). However, intracranial hemorrhage (ICH) associated with neurological deterioration occurred more frequently with IA rtPA therapy than with control (10 percent vs. 2 percent; p=0.06). Despite the safety concerns, this was the first trial that attempted to treat a large vessel occlusion ischemic stroke by endovascular means. Interestingly, Ciccone and colleagues recently performed a randomized controlled trial comparing IV rtPA with IA rtPA in 54 ischemic stroke patients with an average baseline NIHSS of 16–17.^36^ Although the time from stroke onset was significantly shorter in the IV rtPA group, a trend towards improved survival in the IA rtPA group was seen (p=0.067). Thus, a treatment modality that could preserve the clinical advantages of IA rtPA over IV rtPA without the associated bleeding risk would be ideal.

## Advances in Recanalization Using Neurothrombectomy Devices

Neurothrombectomy devices have been examined for use in patients presenting with acute ischemic stroke as an alternative to IV rtPA therapy either due to ineligibility, prior therapy failure, or identification of occlusions less likely to respond to IV rtPA. A neurothrombectomy device is defined by the FDA’s Center for Devices and Radiological Health (CDRH) as a device intended to retrieve or destroy blood clots in the cerebral neurovasculature by mechanical, laser, ultrasound technologies, or combination of technologies.37 These devices may offer a number of potential advantages when compared to pharmacologic thrombolysis including: more rapid achievement of recanalization vs. IV rtPA; enhanced efficacy in treating large vessel occlusions; greater efficacy with a lower risk for hemorrhagic events; and use in patients contraindicated to, or presenting outside the appropriate window for, IV rtPA.38 These putative advantages of neurothrombectomy devices have not been confirmed in direct comparisons against rtPA therapy. Neurothrombectomy devices employing different mechanisms including clot retrievers, aspiration/suction devices, snare-like devices, ultrasonography technologies and lasers, have been or are currently under study in patients with acute ischemic stroke. The MERCI clot retriever was the first neurothrombectomy device to receive FDA clearance in 2004 to “restore blood flow in the neurovasculature by removing thrombus in patients experiencing ischemic stroke”.39–42 Subsequently, the Penumbra System was cleared by the FDA in 2007 “for use in the revascularization of patients with acute ischemic stroke secondary to intracranial large vessel occlusive disease within 8 hours of symptom onset.”42 These clearances through the FDA 510(k) process resulted in significant controversy given the relatively low number of patients included in the studies available at the time of clearance as well as the lack of clinical outcomes compared to contemporaneous controls.31 Various ongoing clinical trials are currently evaluating the impact of these, as well as other, neurothrombectomy devices for the treatment of acute ischemic stroke.

## Statement of Work

The goal of this technical brief is to describe neurothrombectomy devices currently being used or actively investigated in the treatment of patients with acute ischemic stroke, and to summarize the evidence supporting their use.

This technical brief is based on a systematic scan of the literature. Key questions, methods, and approaches were defined by the University of Connecticut/Hartford Hospital Evidence-based Practice Center (EPC) after discussions with representatives from the Agency for Healthcare Research and Quality (AHRQ) and clinical content and technical experts.

## The Key Questions

Population. The population consists of patients with acute ischemic stroke.

Intervention. The intervention is the use of a neurothrombectomy device with or without prior intravenous thrombolytics or concomitant intra-arterial therapy (thrombolytics, angioplasty or stenting).

Comparators. Studies are not required to have comparators.

Outcomes. The outcomes are separated into adverse events (e.g., failure to deploy the device or remove the clot, device breakage/fracture, perforation, dissection, thrombus formation (proximal, adjacent, or distal to the clot site), vasospasm or hemorrhage (intracerebral and other)), intermediate outcomes (e.g. recanalization), and final health outcomes (e.g. mortality and impact of therapy on the mRS, NIHSS, Barthel Index, and GOS).

Timing. The timing is not restrictive as long as the intervention was initiated within the period of the acute ischemic stroke.

Setting. The setting is not limited.

Key Question 1. What are the different types of neurothrombectomy devices in use or in development for treatment of acute ischemic stroke?

1a What are the existing FDA indications for each device?
1b Which devices are being used off-label for this indication?
1c What is the status of FDA approval for each device?
1d What are the theoretical advantages and disadvantages of these devices compared to other treatment options?
1e What are the potential safety issues and harms associated with the use of these devices?
1f What is the extent of utilization of the different devices?

Key Question 2. From a systematic scan of studies of different types of neurothrombectomy devices, what are the type(s) of devices, study designs and sizes, patient characteristics, comparators used in comparative studies, lengths of follow-up, concurrent or prior therapies, outcomes measured, and adverse events, harms, and safety issues reported?

2a Type(s) of devices
2b Study design and size
2c Patient characteristics
2d Comparator used in comparative studies
2e Length of follow-up
2f Concurrent or prior therapy
2g Outcomes measured
2h Adverse events, harms and safety issues reported

Key Question 3. What are the variables associated with use of the devices that may impact outcomes (e.g. time to deployment, training/expertise of interventionalist, location of infarct, concurrent therapies)?

## Analytic Framework

To guide our assessment of studies examining the association between neurothrombectomy devices with benefits and harms in our target population, we developed an analytic framework mapping specific linkages from comparisons to populations of interest, mechanisms of benefit, and outcomes of interest (Figure 1). It is a logic chain that supports the link from the intervention to the outcomes of interest.

Figure 1 Analytic framework for neurothrombectomy devices for treatment of acute ischemic stroke

Legend: GOS=Glasgow Outcome Scale; IV/IA=intravenous or intraarterial; KQ=key question; mRS=modified Rankin Scale; rtPA=recombinant tissue plasminogen activator; NIHSS=National Institutes of Health Stroke Scale.

This analytic framework figure is intended as an overview only and provides links between the use of an intervention in a population and outcomes. The population includes patients experiencing a documented acute ischemic stroke. The intervention is the use of a neurothrombectomy device with or without IV thrombolytic therapy or concurrent IA therapies (IA thrombolysis, angioplasty, stenting). While most studies do not have comparators, the comparator in current clinical practice would be IV thrombolytic therapy in the patient reporting within 4.5 hours of symptom onset.25,27,30 The outcomes are separated into adverse events, intermediate outcomes, and final health outcomes. The adverse events of note include failure of the device to employ, breakage or fracture, perforation, dissection, adjacent thrombosis, vasospasm, and hemorrhage. The intermediate outcome is recanalization. The final health outcomes include mortality and impact of therapy on the mRS, NIHSS score, Barthel Index, and GOS.