# Appendixes

Appendix A MEDLINE and CENTRAL Search Strategies

Appendix B Citations for Included and Excluded Reports

Appendix C Tables of Included Study Characteristics, Inclusion and Exclusion Criteria

Appendix D Summary Figures and Tables