# Summary Figures and Tables

Figure D1 Proportion of patients achieving recanalization with MERCI retriever

CI=confidence interval; n=number of patients with outcome; N=total number of patients evaluated

Figure D2 Proportion of patients achieving recanalization with Penumbra System

CI=confidence interval; n=number of patients with outcome; N=total number of patients evaluated

Figure D3 Proportion of patients achieving recanalization with off-label neurothromectomy devices

CI=confidence interval; n=number of patients with outcome; N=total number of patients evaluated

This figure shows the eight prospective studies that provided data on recanalization for off-label devices. The proportion of patients achieving recanalization in each study ranged from 0.41 to 0.90.

Table D1 Key efficacy endpoint results of prospective, single-arm or retrospective studies of the Penumbra System (Penumbra, Alameda, CA)

| | | | Outcome, n/N (%)
Study, yr | Device | Design | Blinded Outcome Assessment | TIMI II/III | NIHSS decrease ≥ 4^#^ | mRS ≤ 2^*^ | Death^
Kulcsar, 2010 | Penumbra | Prospective | Unclear/No | 25/27 (93) | 15/27 (56) | 13/27 (48) | 3/27 (11)
PPST, 2009 | Penumbra | Prospective | Yes | 102/125 (81.6) | 27/125 (21.6) | 25/125 (20.0) | 33/125 (26.4)
Grunwald, 2009 | Penumbra | Prospective | Unclear/No | 25/29 (86.2) | 19/29 (65.5) | 11/29 (37.9) | 4/29 (13.8)
Bose, 2008 | Penumbra | Prospective | Yes | 20/20 (100) | 9/20 (45.0) | 7/20 (35.0) | 9/20 (45.0)
Struffert, 2009 | Penumbra | Retrospective | Unclear/No | 12/15 (80.0) | 11/15 (73.3) | 5/15 (33.3) | 3/15 (20.0)
Tarr, 2009 | Penumbra | Retrospective | Unclear/No | 87/105 (82.9) | 59/105 (56.2) | 34/105 (32.4) | 22/105 (21.0)
Frei, 2009 | Penumbra | Retrospective | Unclear/No | 44/53 (83.0) | 30/53 (56.6) | 19/53 (35.8) | 19/53 (35.8)

mRS=modified Rankin Scale; n=number of patients with outcome; N=total number of patients evaluated; NIHSS=National Institutes of Health Stroke Scale; PPST=Penumbra Pivotal Stroke Trial; TIMI=Thrombolysis in Myocardial Infarction

# NIHSS decrease of at least 4-points at 30-days except PPST, 2009 (NIHSS 0-1 or improved by at least 10-points at discharge); Tarr, 2009 and Frei, 2009 (each assessed only at discharge).

* mRS at 90-days except Grunwald, 2009 and Bose, 2008 (30-day)

^ Death at 90-days except Grunwald, 2009 and Bose, 2008 (30-day)

Table D2 Key efficacy endpoint results of prospective, single-arm or retrospective studies of the MERCI Retrieval System (Concentric Medical Inc., Mountain View, CA)

| | | | Outcome, n/N (%)
Study, yr | Device | Design | Blinded Outcome Assessment | TIMI II/III | NIHSS decrease ≥ 4^#^ | mRS ≤ 2^*^ | Death^
Loh, 2010 | MERCI | Prospective | Unclear/No | 71/97 (73) | - | - | -
Smith, 2008 | MERCI | Prospective | Unclear/No | 90/164 (54.9) | 38/146 (26.0) | 59/164 (36.0) | 56/164 (34.1)
Devlin, 2007 | MERCI | Prospective | Unclear/No | 14/25 (56.0) | - | 6/25 (24.0) | 9/25 (36.0)
Kim, 2006 | MERCI | Prospective | Unclear/No | 13/24 (54.2) | - | 6/24 (25.0) | 7/24 (29.2)
Smith, 2005 | MERCI | Prospective | Unclear/No | 68/141 (48.2) | 46/141 (32.6) | 36/130 (27.7) | 60/138 (43.5)
Gobin, 2004 | MERCI | Prospective | Unclear/No | 12/28 (42.9) | - | 6/28 (21.4) | 10/28 (35.7)
Lin, 2009 | MERCI | Retrospective | Unclear/No | 24/34 (70.6) | - | - | -
Jo, 2008 | MERCI | Retrospective | Unclear/No | 75/114@ (65.8) | - | - | -
Madison, 2008 | MERCI | Retrospective | Unclear/No | 28/54 (51.9) | - | - | -
Kidwell, 2008 | MERCI | Retrospective | Yes | 14/18 (77.8) | - | - | -

mRS=modified Rankin Scale; n=number of patients with outcome; N=total number of patients evaluated; NIHSS=National Institutes of Health Stroke Scale; TIMI=Thrombolysis in Myocardial Infarction

# NIHSS decrease of at least 4-points at 30-days except Smith, 2008 (NIHSS improved by at least 10-points or 0 score at 24-hours); Smith, 2005 (NIHSS improved by at least 10-points at 90-days)

@ TICI II/III not TIMI II/III for Jo, 2008

* mRS at 90-days except Gobin, 2004 (30-day)

^ Death at 90-days except Gobin, 2004 (30-day)

Table D3 Key efficacy endpoint results of prospective, single-arm or retrospective studies of off-label neurothrombectomy devices

| | | | Outcome, n/N (%)
Study, yr | Device | Design | Blinded Outcome Assessment | TIMI II/III | NIHSS decrease ≥ 4^#^ | mRS ≤ 2^*^ | Death^
Liebig, 2008 | Phenox | Prospective | Unclear/No | 27/45 (60.0) | - | - | -
Tomsick, 2008 | EKOS Primo | Prospective | Yes | 18/29@ (62.1) | - | - | -
Mahon, 2003 | EKOS MicroLysUS | Prospective | Unclear/No | 10/14 (71.4) | 8/14 (57.1) | 5/14 (35.7) | 5/14 (35.7)
Gonzalez, 2007 | Amplatz Gooseneck | Prospective | Unclear/No | 7/9 (77.8) | 3/7 (42.9) | 2/7 (28.6) | 2/7 (28.6)
Mayer, 2005 | AngioJet | Prospective | Unclear/No | 9/10 (90.0) | - | 4/12 (33.3) | 3/10 (30.0)
Berlis, 2004 | EPAR | Prospective | Unclear/No | 14/34 (41.2) | 7/34 (20.6) | 5/34 (14.7) | 13/34 (38.2)
Mayer, 2002 | Neuronet | Prospective | Unclear/No | 3/5 (60.0) | 4/5 (80.0) | 3/5 (60.0) | 0/5 (0)
Clark, 2000 | LaTIS | Prospective | Unclear/No | 1/2 (50.0) | - | - | -

EPAR=Endovascular Photoacoustic Recanalization; mRS=modified Rankin Scale; n=number of patients with outcome; N=total number of patients evaluated; NIHSS=National Institutes of Health Stroke Scale; TIMI=Thrombolysis in Myocardial Infarction

@ TICI II/III not TIMI II/III for Tomsick, 2008

# NIHSS decrease of at least 4-points at 90-days except Berlis 2004 (30-day, NIHSS ≥ 50% decrease)

* mRS at 90-days except Berlis, 2004 (30-day)

^ Death at 90-days except Berlis, 2004 (30-day)

Table D4 Key safety endpoint results of prospective, single-arm or retrospective studies of the Penumbra System (Penumbra, Alameda, CA)

| | | Outcome, n/N (%)
Study, yr | Device | Design | SICH | AICH | Other Hemorrhage | Perforation/Dissection | Thrombus Formation
Kulcsar, 2010 | Penumbra | Prospective | 0/27 (0) | - | - | - | -
PPST, 2009 | Penumbra | Prospective | 14/125 (11.2) | 21/125 (16.8) | - | 6/125 (4.8) | 1/125 (0.8)
Grunwald, 2009 | Penumbra | Prospective | 2/29 (6.9) | 3/29 (10.3) | - | - | -
Bose, 2008 | Penumbra | Prospective | 2/20 (10.0) | 6/20 (30.0) | 2/20 (10.0) | 0/20 (0) | 0/20 (0)
Struffert, 2009 | Penumbra | Retrospective | 0/15 (0) | - | 0/15 (0) | 0/15 (0) | 0/15 (0)
Tarr, 2009 | Penumbra | Retrospective | 5/105 (4.8) | 1/105 (1.0) | - | - | -
Frei, 2009 | Penumbra | Retrospective | 3/53 (5.7) | 5/53 (9.4) | - | - | -

AICH=asymptomatic intracerebral hemorrhage; n=number of patients with outcome; N=total number of patients evaluated; PPST=Penumbra Pivotal Stroke Trial; SICH=symptomatic intracerebral hemorrhage

Table D5 Key safety endpoint results of prospective, single-arm or retrospective studies of the MERCI Retrieval System (Concentric Medical Inc., Mountain View, CA)

| | | Outcome, n/N (%)
Study, yr | Device | Design | SICH | AICH | Other Hemorrhage | Perforation/Dissection | Thrombus Formation
Loh, 2010 | MERCI | Prospective | - | - | 16/27 (59) | 2/27 (7) | -
Smith, 2008 | MERCI | Prospective | 16/164 (9.8) | 50/164 (30.5) | - | - | -
Devlin, 2007 | MERCI | Prospective | 1/25 (4.0) | 7/25 (28.0) | 2/25 (8.0) | 0/25 (0) | -
Kim, 2006 | MERCI | Prospective | 2/24 (8.3) | 9/24 (37.5) | - | 0/24 (0) | 0/24 (0)
Smith, 2005 | MERCI | Prospective | 11/141 (7.8) | 39/141 (27.7) | 7/141 (5.0) | 10/141 (7.1) | 3/141 (2.1)
Gobin, 2004 | MERCI | Prospective | 0/28 (0) | 12/28 (42.9) | - | - | -
Lin, 2009 | MERCI | Retrospective | - | - | - | - | -
Jo, 2008 | MERCI | Retrospective | - | - | - | - | -
Madison, 2008 | MERCI | Retrospective | - | - | - | - | -
Kidwell, 2008 | MERCI | Retrospective | - | - | - | - | -

AICH=asymptomatic intracerebral hemorrhage; n=number of patients with outcome; N=total number of patients evaluated; SICH=symptomatic intracerebral hemorrhage

Table D6 Key safety endpoint results of prospective, single-arm or retrospective studies of off-label neurothrombectomy devices

| | | Outcome, n/N (%)
Study, yr | Device | Design | SICH | AICH | Other Hemorrhage | Perforation/Dissection | Thrombus Formation
Liebig, 2008 | Phenox | Prospective | - | - | - | - | -
Tomsick, 2008 | EKOS Primo | Prospective | 7/29 (24.1) | - | - | 0/29 (0) | -
Mahon, 2003 | EKOS MicroLysUS | Prospective | 2/14 (14.3) | - | - | 0/14 (0) | -
Gonzalez, 2007 | Amplatz Gooseneck | Prospective | 1/7 (14.3) | 1/7 (14.3) | - | 0/7 (0) | 0/7 (0)
Mayer, 2005 | AngioJet | Prospective | 3/12 (25.0) | 2/12 (16.7) | - | 0/12 (0) | 1/12 (8.3)
Berlis, 2004 | EPAR | Prospective | 2/34 (5.9) | 2/34 (5.9) | - | 0/34 (0) | -
Mayer, 2002 | Neuronet | Prospective | - | - | - | - | 2/5 (40.0)
Clark, 2000 | LaTIS | Prospective | - | - | - | - | -

AICH=asymptomatic intracerebral hemorrhage; EPAR=Endovascular Photoacoustic Recanalization; n=number of patients with outcome; N=total number of patients evaluated; SICH=symptomatic intracerebral hemorrhage

Table D7 All device failure to-deploy or breakage/fracture

| | | Outcome, n/N (%)
Study, yr | Design | Device | Failure to Deploy | Breakage/Fracture
Kulcsar, 2010 | Penumbra | Prospective | - | -
PPST, 2009 | Penumbra | Prospective | 0/125 (0) | -
Grunwald, 2009 | Penumbra | Prospective | 0/29 (0) | -
Bose, 2008 | Penumbra | Prospective | 3/23 (13.0) | -
Struffert, 2009 | Penumbra | Retrospective | 0/15 (0) | 0/15 (0)
Tarr, 2009 | Penumbra | Retrospective | - | 0/7 (0)
Frei, 2009 | Penumbra | Retrospective | - | -
Loh, 2010 | MERCI | Prospective | - | -
Smith, 2008 | MERCI | Prospective | 13/177 (7.3) | 1/164 (0.6)
Devlin, 2007 | MERCI | Prospective | - | 1/25 (4.0)
Kim, 2006 | MERCI | Prospective | - | 3/24 (12.5)
Smith, 2005 | MERCI | Prospective | 10/151(6.6) | 11/341^*^ (3.2)
Gobin, 2004 | MERCI | Prospective | 2/30 (6.7) | 1/30 (3.3)
Lin, 2009 | MERCI | Retrospective | - | -
Jo, 2008 | MERCI | Retrospective | - | -
Madison, 2008 | MERCI | Retrospective | - | -
Kidwell, 2008 | MERCI | Retrospective | - | -
Liebig, 2008 | Phenox | Prospective | 3/45 (6.7) | -
Tomsick, 2008 | EKOS Primo | Prospective | 6/35 (17.1) | -
Mahon, 2003 | EKOS MicroLysUS | Prospective | - | 1/14 (7.1)
Gonzalez, 2007 | Amplatz Gooseneck | Prospective | 2/9 (22.2) | -
Mayer, 2005 | AngioJet | Prospective | 2/12 (16.7) | -
Berlis, 2004 | EPAR | Prospective | 16/34 (47.1) | -
Mayer, 2002 | Neuronet | Prospective | 1/5 (20.0) | -
Clark, 2000 | LaTIS | Prospective | - | -

EPAR=Endovascular Photoacoustic Recanalization; n=number of patients with outcome; N=total number of patients evaluated; PPST=Penumbra Pivotal Stroke Trial

* Refers to number of breakages/fractures divided by total number of devices used.