# Tables of Included Study Characteristics, Inclusion and Exclusion Criteria

Table C1 Characteristics of prospective, single-arm or retrospective studies of the Penumbra System (Penumbra, Alameda, CA)

Study, yr N | Device | Design | Inclusion Criteria | Exclusion Criteria | Baseline Characteristics (mean/median) | Location of Emboli (%)
Kulcsar, 2010 N=27 | Penumbra | Prospective | Patients not responding to initial IV rtPA or presenting >4 hours from symptom onset | NR | NIHSS: 14 Age: 66 Female %: 48 TICI 0/1 %: 100 ST: 266 minutes | ICA/ICA-T: 19 MCA: 66 VB = 15
PPST, 2009 N=125 | Penumbra | Prospective | NIHSS ≥ 8, presentation <8 hours from symptoms onset, angiographic TIMI 0/1 occlusion of a treatable large, intracranial vessel, ineligible or refractory to IV rtPA if presenting <3 hours from symptom onset | Infarction greater than one- third of the MCA, severe edema, intracerebral hemorrhage and pregnancy | NIHSS: 18 Age: 64 Female %: 49 TIMI 0/1 %: 100 ST: 258 minutes | ICA/ICA-T: 18 MCA: 70 VB: 9 Other: 3
Grunwald, 2009 N=29 | Penumbra | Prospective | NIHSS ≥ 8, >18 years of age, presentation <8 hours from symptom onset, TIMI 0/1 occlusion of a treatable large, intracranial vessel, ineligible or refractory to IV rtPA if presenting <3 hours from symptom onset | Brain edema or intracerebral hemorrhage | NIHSS: 20 Age: 58 Female %: 48 TIMI 0/1%: 100 ST: 312 minutes | ICA/ICA-T: 28 MCA: 52 VB: 21 Other: 0
Bose, 2008 N=23 | Penumbra | Prospective | >18 years of age, presentation <8 hours from symptoms onset, angiographic TIMI 0/1 occlusion of a treatable large, intracranial vessel, ineligible or refractory to IV rtPA if presenting <3 hours from symptom onset | Risk of bleeding, vessels deemed too tortuous for Penumbra system, uncontrolled hypertension and pregnancy | NIHSS: 21 Age: 60 Female %: 40 TIMI 0/1%: 100 ST: 50% > 3 hours from symptoms | ICA/ICA-T: 33 MCA: 24 VB: 43 Other: 0
Struffert, 2009 N=15 | Penumbra | Retrospective | Consecutive patients with large vessel occlusion (ICA, MCA, BA). Inclusion and exclusion criteria of Bose, 2009 (see above) followed except IV rtPA allowed between 3–9 hours if perfusion imaging mismatch is visible on MRI | NR | NIHSS: 15 Age: 60 Female %:40 TIMI 0%: 100 ST: 151 minutes | ICA/ICA-T: 33 MCA: 47 VB: 20 Other: 0
Tarr, 2009 N=105 (Abstract Only) | Penumbra | Retrospective | NIHSS ≥ 8, presentation <8 hours from symptom onset, TIMI 0/1 occlusion of a treatable large, intracranial vessel (consistent with device approval indication) | NR | NIHSS: 17 Age: 64 Female %: NR TIMI 0/1%: 96 ST: 141 minutes | NR
Frei, 2009 N=53 (Abstract Only) | Penumbra | Retrospective | Failed IV rtPA prior to therapy | NR | NIHSS: 18 Age: 66 Female %:55 TIMI 0/1 %: 100 ST: NR | NR

BA=basilar artery; ICA=internal carotid artery; ICA-T=internal carotid artery terminus; IV rtPA=intravenous recombinant tissue plasminogen activator; MCA=middle cerebral artery; N=total number of patients evaluated; NIHSS=National Institutes of Health Stroke Scale; NR=not reported; PPST=Penumbra Pivotal Stroke Trial; TIMI=Thrombolysis in Myocardial Infarction; ST=symptom time (to angiography or device deployment); VB=vertebrobasilar

Table C2 Characteristics of prospective, single-arm or retrospective studies of the MERCI retrieval system (Concentric Medical Inc., Mountain View, CA)

Study, yr N | Device | Design | Inclusion Criteria | Exclusion Criteria | Baseline Characteristics (mean/median) | Location of Emboli (%)
Loh, 2010 N=97 | MERCI | Prospective | Consecutive patients undergoing MERCI retrieval for large cerebral artery occlusion acute ischemic strokes. | NR | NIHSS: NR Age: 65–68 Female %: 58 TIMI 0/1 %: NR ST: 403–417 minutes | NR
Smith, 2008 N=164 | MERCI | Prospective | NIHSS ≥ 8, >18 years of age, presentation <8 hours from symptoms onset, angiographic TIMI 0/1 occlusion of a treatable large, intracranial vessel (ICA, ICA-T, MCA M1 or M2), ineligible or refractory to IV rtPA if presenting <3 hours from symptom onset, otherwise similar to Smith, 2005 | Excessive tortuosity of vessels, pregnancy, allergy to contrast media, life expectancy < 3months, >50% stenosis of the artery proximal to target vessel, glucose <50 mg/dL, prothrombin time>2 times normal, hemorrhagic diathesis, coagulation factor deficiency, oral anticoagulation with INR>3, use of heparin with partial thrombplastin time >2 times normal, platelets <30,000, severe hypertension, CT scan showing significant mass effect with midline shift | NIHSS: 19 Age: 68 Female %: 57 TIMI 0/1 %: NR ST: 258 minutes | ICA/ICA-T: 32 MCA: 60 VB: 8 Other: 0
Devlin, 2007 N=25 | MERCI | Prospective | NIHSS ≥ 8, >18 years of age, presentation <8 hours from symptoms onset, occlusion of a treatable large, intracranial vessel (ICA, ICA-T, MCA M1 or M2), ineligible or refractory to IV rtPA if presenting <3 hours from symptom onset (n=9 were treated with IV rtPA after 3-hours, n=8 were treated for 50% stenosis of proximal carotid) | Hypodensity >one-third of MCA on CT, glucose <50 mg/dL, hemorrhagic diathesis, coagulation factor deficiency, oral anticoagulation with INR>3, use of heparin in past 48 hours with partial thrombplastin time >2 times normal, platelets <30,000, severe hypertension, CT scan showing significant mass effect with midline shift, life expectancy <3 months | NIHSS: 18 Age: 63 Female %: 36 TIMI 0/1 %: 96 ST: 312 minutes | ICA/ICA-T: 12 MCA: 48 VB: 8 Tandem ICA/MCA: 32
Kim, 2006 N=24 | MERCI | Prospective | NIHSS ≥ 8, presentation <8 hours from symptoms onset, angiographic TIMI 0/1 occlusion of a treatable large, intracranial vessel, ineligible or refractory to IV rtPA if presenting <3 hours from symptom onset, otherwise similar to Gobin, 2004 and Smith, 2005 | No large mismatch between core infarct and salvageable penumbra, enrolled in Gobin, 2004 and Smith, 2005 | NIHSS: 21 Age: 64 Female %: 42 TIMI 0/1 %: NR ST: 303 minutes | ICA/ICA-T: 38 MCA: 58 VB: 4 Other: 0
Smith, 2005 N=151 | MERCI | Prospective | NIHSS ≥ 8, >18 years of age, presentation <8 hours from symptoms onset, angiographic TIMI 0/1 occlusion of a treatable large, intracranial vessel, ineligible for IV rtPA if presenting <3 hours from symptom onset | Excessive tortuosity of cervical vessels, pregnancy, allergy to contrast media, life expectancy < 3months, >50% stenosis of the artery proximal to target vessel, glucose <50 mg/dL, prothrombin time >2 times normal, hemorrhagic diathesis, coagulation factor deficiency, oral anticoagulation with INR>1.7 in part 1 and >3.0 in part 2, use of heparin within 48 hours and a partial thromboplastin time >2 times normal, platelets <50,000 (<30,000 in part 2), severe hypertension, CT scan showing significant mass effect with midline shift, < one-third of the MCA region with hypodensity, life expectancy < 3 months | NIHSS: 20 Age: 67 Female %: 46 TIMI 0/1 %: NR ST: 258 minutes | ICA/ICA-T: 33 MCA: 57 VB: 10 Other: 0
Gobin, 2004 N=30 | MERCI | Prospective | NIHSS ≥ 10, >18 years of age, presentation <8 hours from symptoms onset, angiographic TIMI 0/1 occlusion of a treatable large, intracranial vessel, ineligible for IV rtPA if presenting <3 hours from symptom onset | Hypodensity >one-third of MCA on CT, glucose <50 mg/dL, seizure at stroke onset, prothrombin time >15 seconds, hemorrhagic diathesis, coagulation factor deficiency, oral anticoagulation with INR >3, use of heparin with partial thrombplastin time >2 times normal, platelets <50,000, severe hypertension, CT scan showing significant mass effect with midline shift, severe arterial stenosis proximal to thrombus precluding thrombus removal | NIHSS:22 Age: 68 Female %: 50 TIMI 0/1 %: NR ST: 301 minutes | ICA/ICA-T: 18 MCA: 64 VB: 7 Tandem ICA/MCA: 11
Lin, 2009 N=34 | MERCI | Retrospective | Consecutive patients with acute ischemic stroke, occlusion of the ICA with or without extension into the MCA, ineligible or refractory to IV rtPA if presenting <3 hours from symptom onset | NR | NIHSS: NR Age: NR Female %: NR TIMI 0/1 %: NR ST: NR | ICA/MCA: 100
Jo, 2008 N=114 (Abstract Only) | MERCI | Retrospective | Consecutive patients with acute ischemic stroke | NR | NIHSS: 19 Age: 65 Female %: NR TIMI 0/1 %: NR ST: NR | NR
Madison, 2008 N=54 (Abstract Only) | MERCI | Retrospective | Consecutive patients with acute ischemic stroke with angiographically confirmed large vessel occlusion treated with intra- arterial intervention within 6 hours of symptom onset | NR | NIHSS: NR Age: NR Female %: NR TIMI 0/1 %: NR ST: NR | NR
Kidwell, 2008 N=18 | MERCI | Retrospective | Patients within 8 hours of symptom onset and having a baseline MRI scan, FLAIR MRI within 7-days and endpoint data recorded out to 90-days. | Receiving adjunctive thrombolysis | NIHSS: 19 Age: 63 Female %: 39 TIMI 0/1 %: NR ST: NR | NR

BA=basilar artery; FLAIR=fluid attenuated inversion recovery; ICA=internal carotid artery; ICA-T=internal carotid artery terminus; IV rtPA=intravenous recombinant tissue plasminogen activator; MCA=middle cerebral artery; MRI=magnetic resonance imaging; N=total number of patients evaluated; NIHSS=National Institutes of Health Stroke Scale; NR=not reported; PPST=Penumbra Pivotal Stroke Trial; TIMI=Thrombolysis in Myocardial Infarction; ST=symptom time (to angiography or device deployment); VB=vertebrobasilar

Table C3 Characteristics of prospective, single-arm or retrospective studies of off-label neurothrombectomy devices

Study, yr N | Device | Design | Inclusion Criteria | Exclusion Criteria | Baseline Characteristics (mean/median) | Location of Emboli (%)
Liebig, 2008 N=45 (Abstract Only) | Phenox | Prospective | Patients with ischemic stroke | NR | NIHSS: NR Age: NR Female %: NR TIMI 0/1 %: NR ST: NR minutes | ICA/ICA-T: 27 MCA: 38 VB: 27 Other: 8
Tomsick, 2008^*^ N=35 | EKOS Primo | Prospective | NIHSS ≥ 10, <81 years of age, presenting <3 hours from symptom onset | NR | NIHSS: NR Age: NR Female %: NR TIMI 0/1 %: NR ST: NR | NR
Mahon, 2003 N=14 | EKOS MicroLysUS | Prospective | Patients between 18–77 years with a treatable artery, NIHSS ≥ 8, time from symptom onset of <6 hours for anterior circulation or <24 hours for posterior circulation occlusions, exclusion from IV thrombolysis protocol | Confounding prior neurologic event or hemorrhage on CT scan | NIHSS: 18 Age: 64 Female %: 50 TIMI 0/1 %: NR ST: 331 minutes | ICA/ICA-T: 36 MCA: 36 VB/Other: 28
Gonzalez, 2007 N=9 | Amplatz Gooseneck | Prospective | NIHSS≥ 8, ineligible for IV rtPA, <8 hours since symptoms for anterior and <24 hours for posterior occlusions | CT scan showing hemorrhage or hypoattenuation involving more than one-third of the MCA, history of chronic severe illness, previous disabling stroke, and/or dementia | NIHSS: 16 Age: 55 Female %: NR TIMI 0/1 %: NR ST: 251 minutes | ICA/ICA-T: 11 MCA: 56 VB: 33 Other: 0
Mayer, 2005 N=12 | AngioJet | Prospective | Consecutive patients with VB occlusion confirmed by angiography, diameter >2mm in vessel to be treated | Coma >8 hours, >80 years of age, acute intracerebral hemorrhage and extensive brain stem or thalamic infarction by CT or MRI | NIHSS: 20 Age: 56 Female %: 25 TIMI 0/1 %: 100 ST: 5–216 hours | ICA/ICA-T: 0 MCA: 0 VB: 100 Other: 0
Berlis, 2004 N=34 | EPAR | Prospective | Patients 18–85 years, NIHSS >3, stroke <7 hours from projected EPAR use if anterior and ≤ 24 hours if posterior occlusion, occlusion of the ICA, MCA, PCA, basilar or vertebral arteries, diameter >2mm, TIMI 0–1 flow | Pregnancy, evidence of aneurysm or dissection, uncontrolled bleeding diathesis, blood pressure >200 mmHg systolic, 120 mmHg diastolic, intracranial tumor or massive infarct, markedly increasing improvement of neurologic symptoms by time of treatment initiation, evidence of intracranial hemorrhage | NIHSS: 19 Age: 68 Female %: 50 TIMI 0/1 %: 100 ST: 382 minutes | ICA/ICA-T: 29 MCA: 35 VB: 32 Other: 3
Mayer, 2002 N=5 | Neuronet | Prospective | NR | NR | NIHSS: 20 Age: 42 Female %: 20 TIMI 0/1 %: 100 ST: 388 minutes | ICA/ICA-T: 0 MCA: 0 VB: 100 Other: 0
Clark, 2000 N=2 (Abstract Only) | LaTIS | Prospective | NIHSS >5, treated within 8 hours for anterior and <24 for posterior occlusion, TIMI 0, and a vessel diameter of 2–5 mm. | NR | NIHSS: 20/26 Age: NR Female %: NR TIMI 0/1 %: 100 ST: 479/270 minutes | ICA/ICA-T: 0 MCA: 100 VB: 0 Other: 0

CT=computed tomography; EPAR=Endovascular Photoacoustic Recanalization; ICA=internal carotid artery; ICA-T=internal carotid artery terminus; IV rtPA=intravenous recombinant tissue plasminogen activator; MCA=middle cerebral artery; N=total number of patients evaluated; N=total number of patients evaluated; NIHSS=National Institutes of Health Stroke Scale; NR=not reported; PCA=posterior cerebral artery; PPST=Penumbra Pivotal Stroke Trial; TIMI=Thrombolysis in Myocardial Infarction; ST=symptom time (to angiography or device deployment); VB=vertebrobasilar

* Data from Tomsick, 2008 publication of Interventional management of Stroke (IMS)-II Trial. Data for EKOS Primo only

Table C4 Characteristics of prospective, single-arm or retrospective studies of stent retriever devices

Study, yr N | Device | Design | Inclusion Criteria | Exclusion Criteria | Baseline Characteristics (mean/median) | Location of Emboli (%)
Castano, 2010 N=20 | Solitaire AB | Prospective | NIHSS ≥ 8, refractory or ineligible for IV rtPA, <8 hours since symptoms for anterior, absence of large signs of ischemia, angiographically proven arterial circulation occlusion | NR | NIHSS: 19 Age: 65 Female %: 50 TIMI 0/1 %: 90 ST: 352 minutes | ICA/ICA-T: 25 MCA: 55 VB: 0 Other: 20
Mocco, 2009 N=18 (Abstract Only) | Solitaire | Prospective | NR | NR | NIHSS: NR Age: NR Female %:NR TIMI 0/1 %: NR ST: NR | ICA/ICA-T: 11 MCA: 67 VB: 0 Other: 22

ICA=internal carotid artery; ICA-T=internal carotid artery terminus; IV rtPA=intravenous recombinant tissue plasminogen activator; MCA=middle cerebral artery; N=total number of patients evaluated; N=total number of patients evaluated; NIHSS=National Institutes of Health Stroke Scale; NR=not reported; PCA=posterior cerebral artery; TIMI=Thrombolysis in Myocardial Infarction; ST=symptom time (to angiography or device deployment); VB=vertebrobasilar