# Citations for Included and Excluded Reports

## Citations for Included Reports

1 Abelson M, Roos J, Rymer M. Mechanical thrombo-embolectomy in acute ischaemic stroke: A local experience. Cardiovasc J Afr. 2008;19:204-7. [pmid: 18776966].
2 Abou-Chebl A, Bajzer CT, Krieger DW, et al. Multimodal therapy for the treatment of severe ischemic stroke combining GPIIb/IIIa antagonists and angioplasty after failure of thrombolysis. Stroke. 2005;36:2286-8. [pmid: 16179581].
3 Agner C, Deshaies EM, Bernardini GL, et al. Coronary AngioJet catheterization for the management of dural venous sinus thrombosis: Technical note. J Neurosurg. 2005;103:368-71. [pmid: 16175870].
4 Bellon RJ, Putman CM, Budzik RF, et al. Rheolytic thrombectomy of the occluded internal carotid artery in the setting of acute ischemic stroke. Am J Neuroradiol. 2001;22:526-30. [pmid: 11237980].
5 Bergui M, Stura G, Daniele D, et al. Mechanical thrombolysis in ischemic stroke attributable to basilar artery occlusion as first-line treatment. Stroke. 2006;37:145-50. [pmid: 16339473].
6 Berlis A, Lutsep H, Barnwell S, et al. Mechanical thrombolysis in acute ischemic stroke with endovascular photoacoustic recanalization. Stroke. 2004;35:1112-6. [pmid: 15017011].
7 Bose A, Henkes H, Alfke K, et al. The penumbra system: A mechanical device for the treatment of acute stroke due to thromboembolism. Am J Neuroradiol. 2008;29:1409-13. [pmid: 18499798].
8 Buck BH, Saver JL. A case of acute ischemic stroke: Optimizing management with penumbra and vessel imaging. Nat Clin Pract Neurol. 2007;3:465-9. [pmid: 17671524].
9 Burns TC, Rodriguez GJ, Patel S, et al. Endovascular interventions following intravenous thrombolysis may improve survival and recovery in patients with acute ischemic stroke: A case-control study. Am J Neuroradiol. 2008;29:1918-24. [pmid: 18784214].
10 Bush RL, Bhama JK, Lin PH, et al. Transient ischemic attack due to early carotid stent thrombosis: Successful rescue with rheolytic thrombectomy and systemic abciximab. J Endovasc Ther. 2003;10:870-4. [pmid: 14656189].
11 Castaño C, Serena J, Dávalos A. Use of the new solitaire™ AB device for mechanical thrombectomy when merci clot retriever has failed to remove the clot: A case report. Interv Neuroradiol. 2009;15:209-14. [pmid: 20465901].
12 Chapot R. First experience with the catch, a new device for cerebral thrombectomy. Interv Neuroradiol. 2005;(Suppl 2):58.
13 Chapot R, Wassef M, Bisdorff A, et al. Occlusion of the middle cerebral artery due to synthetic fibers. Am J Neuroradiol. 2006;27:148-50. [pmid: 16418375].
14 Chiam PT, Samuelson RM, Mocco J, et al. Navigability trumps all: Stenting of acute middle cerebral artery occlusions with a new self-expandable stent. AJNR Am J Neuroradiol. 2008;29:1956-8. [pmid: 18768730].
15 Chopko BW, Kerber C, Wong W, et al. Transcatheter snare removal of acute middle cerebral artery thromboembolism: Technical case report. Neurosurgery. 2000;46:1529-31. [pmid: 10834659].
16 Clarençon F, Blanc R, Gallas S, et al. Thrombectomy for acute basilar artery occlusion by using double merci retriever devices and bilateral temporary vertebral artery flow reversal: Technical note. J Neurosurg. 2009;111:53-6. [pmid: 19249927].
17 Clark WM, Buckley LA, Nesbit GM, et al. Intraarterial laser thrombolysis therapy for clinical stroke: A feasibility study. Stroke. 2000;31:307.
18 Dabus G, Nogueira RG. Empty microcatheter technique for the deployment of a self-expanding stent to treat refractory middle cerebral artery occlusion in the setting of severe proximal tortuosity. J Neuroimaging. 2009;19:164-8. [pmid: 18393952].
19 Devlin TG, Baxter BW, Feintuch TA, et al. The merci retrieval system for acute stroke: The southeast regional stroke center experience. Neurocrit Care. 2007;6:11-21. [pmid: 17356186].
20 DeVries JT, White CJ, Cunningham MC, et al. Catheter-based therapy for acute ischemic stroke: A national unmet need. Catheter Cardiovasc Interv. 2008;72:705-9. [pmid: 18942131].
21 Drake B, Redekop G. Middle cerebral artery embolectomy after failed mechanical clot removal. Can J Neurol Sci. 2010;37:408-11. [pmid: 20481281].
22 du Mesnil de Rochemont R, Sitzer M, Neumann-Haefelin T, et al. Endovascular recanalization of acute atherothrombotic carotid artery occlusion holds up progressive stroke. Neuroradiology. 2004;46:583-6. [pmid: 15168098].
23 Feng L, Mangla S, Pile-Spellman J. Rheolytic thrombectomy of acute stent thrombosis of cervical vertebral artery: Case report and literature review. Interv Neuroradiol. 2002;8:305-11. [pmid: 20594489].
24 Frei D, Bellon R. Mechanical thrombectomy in acute stroke patients who were refractory to intravenous thrombolytic therapy. Stroke. 2009;40:E250.
25 Gobin YP, Starkman S, Duckwiler GR, et al. MERCI 1: A phase 1 study of mechanical embolus removal in cerebral ischemia. Stroke. 2004;35:2848-54. [pmid: 15514171].
26 González A, Mayol A, Martínez E, et al. A. Mechanical thrombectomy with snare in patients with acute ischemic stroke. Neuroradiology. 2007;49:365-72. [pmid: 17262195].
27 Grunwald IQ, Bose A, Struffert T, et al. Images in neurology. Liposuction in mind. Arch Neurol. 2009;66:800-1. [pmid: 19506147].
28 Grunwald IQ, Walter S, Papanagiotou P, et al. Revascularization in acute ischaemic stroke using the penumbra system: The first single center experience. Eur J Neurol. 2009;16:1210-6. [pmid: 19659754].
29 Gupta R. Arterial vasospasm during mechanical thrombectomy for acute stroke. J Neuroimaging. 2009;19:61-4. [pmid: 18801002].
30 Harrigan MR, Levy EI, Bendok BR, et al. Bivalirudin for endovascular intervention in acute ischemic stroke: Case report. Neurosurgery. 2004;54:218-23. [pmid: 14683561].
31 Henkes H, Reinartz J, Lowens S, et al. A device for fast mechanical clot retrieval from intracranial arteries (phenox clot retriever). Neurocrit Care. 2006;5:134-40. [pmid: 17099260].
32 Huded V, Saraf R, Limaye U. Mechanical device the penumbra system in the management of acute stroke: Report of five cases. Neurol India. 2009;57:310-2. [pmid: 19587473].
33 Hui FK, Narayanan S, Cawley CM. Posterior-to-anterior circulation access using the penumbra stroke system for mechanical thrombectomy of a right middle cerebral artery thrombus. World Neurosurg. 2010;73:17-21. [pmid: 20452865].
34 Imai K, Mori T, Izumoto H, et al. Successful thrombectomy in acute terminal internal carotid occlusion using a basket type microsnare in conjunction with temporary proximal occlusion: A case report. Am J Neuroradiol. 2005;26:1395-8. [pmid: 15956505].
35 Ionita CC, Yamamoto J, Tummala RP, et al. MRI assessment followed by successful mechanical recanalization of a complete tandem (internal carotid/middle cerebral artery) occlusion and reversal of a 10-hour fixed deficit. J Neuroimaging. 2008;18:93-5. [pmid: 18190504].
36 Jo KD, Saver JL, Starkman S, et al. Predictors of recanalization with mechanical thrombectomy for acute ischemic stroke. Stroke. 2008;39:599.
37 Kawamura A, Tilem M, Gossman DE. Rheolytic thrombectomy for thromboembolic occlusion of the internal carotid artery complicating coronary intervention. J Invasive Cardiol. 2006;18:E108-10. [pmid: 16495604].
38 Kerber CW, Barr JD, Berger RM, et al. Snare retrieval of intracranialthrombus in patients with acute stroke. J Vasc Interv Radiol. 2002;13:1269-74. [pmid: 12471193].
39 Kerber CW, Wanke I, Bernard J Jr, et al. Rapid intracranial clot removal with a new device: The alligator retriever. Am J Neuroradiol. 2007;28:860-3. [pmid: 17494657].
40 Kidwell CS, Latour L, Saver JL, et al. Thrombolytic toxicity: Blood brain barrier disruption in human ischemic stroke. Cerebrovasc Dis. 2008;25:338-43. [pmid: 18303253].
41 Kim D, Jahan R, Starkman S, et al. Endovascular mechanical clot retrieval in a broad ischemic stroke cohort. Am J Neuroradiol. 2006;27:2048-52. [pmid: 17110664].
42 Kim D, Liebeskind D, Starkman S, Ovbiagele B, et al. Time to recanalization for acute endovascular stroke therapies. Neurology. 2006;66:A159.
43 Kobayashi A, Czepiel W, Dowzenko A, et al. Mechanical embolectomy in acute ischaemic stroke -report of the first two cases. Neurol Neurochir Pol. 2008;42:451-7. [pmid: 19105114].
44 Kulcsar Z, Bonvin C, Pereira VM, et al. Penumbra system: A novel mechanical thrombectomy device for large-vessel occlusions in acute stroke. Am J Neuroradiol. 2010;31:628-33. [pmid: 20019113].
45 Kuruvilla A, Norris GM, Manjila S, et al. Factor v leiden mutation in reocclusion after intra-arterial thrombolysis. Stroke. 2009;40:660-2. [pmid: 18927452].
46 Lansberg MG, Fields JD, Albers GW, et al. Mechanical thrombectomy following intravenous thrombolysis in the treatment of acute stroke. Arch Neurol. 2005;62:1763-5. [pmid: 16286552].
47 Layton KF, White JB, Cloft HJ, et al. Use of the perclose ProGlide device with the 9 french merci retrieval system. Neuroradiology. 2006;48:324-6. [pmid: 16534609].
48 Layton KF, White JB, Cloft HJ, et al. Expanding the treatment window with mechanical thrombectomy in acute ischemic stroke. Neuroradiology. 2006;48:402-4. [pmid: 16586117].
49 Liebeskind DS, Kim D, Starkman S, et al. Collateral failure? Late mechanical thrombectomy after failed intravenous thrombolysis. J Neuroimaging. 2010;20:78-82. [pmid: 18798777].
50 Liebig T, Reinartz J, Guethe T, et al. Early clinical experiences with a new thrombectomy device for the treatment of ischemic stroke. Stroke. 2008;39:608-9.
51 Lin R, Vora N, Zaidi S, et al. Mechanical approaches combined with intra-arterial pharmacological therapy are associated with higher recanalization rates than either intervention alone in revascularization of acute carotid terminus occlusion. Stroke. 2009;40:2092-7. [pmid: 19390066].
52 Loh Y, Jahan R, McArthur DL, et al. Recanalization rates decrease with increasing thrombectomy attempts. Am J Neuroradiol. 2010;31:935-9. [pmid: 20075091].
53 Madison MT, Goddard JK III, Lassig JP, et al. Single center experience with combined (thrombolytics and mechanical thrombectomy) intra-arterial intervention in 112 consecutive patients with angiographically confirmed large vessel thromboembolic ischemic stroke (1–6 hours post symptom onset) from 2003 to 2007. Stroke. 2008;39:547.
54 Mahon BR, Nesbit GM, Barnwell SL, et al. North american clinical experience with the EKOS MicroLysUS infusion catheter for the treatment of embolic stroke. AJNR Am J Neuroradiol. 2003;24:534-8. [pmid: 12637311].
55 Marden FA, Putman CM. Cement-embolic stroke associated with vertebroplasty. AJNR Am J Neuroradiol. 2008;29:1986-8. [pmid: 18617589].
56 Mayer TE, Hamann GF, Brueckmann HJ. Treatment of basilar artery embolism with a mechanical extraction device: Necessity of flow reversal. Stroke. 2002;33:2232-5. [pmid: 12215592].
57 Mayer TE, Hamann GF, Schulte-Altedorneburg G, et al. Treatment of vertebrobasilar occlusion by using a coronary waterjet thrombectomy device: A pilot study. Am J Neuroradiol. 2005;26:1389-94. [pmid: 15956504].
58 Mayer TE, Hmann GF, Brueckmann HJ. Mechanical extraction of a basilar-artery embolus with the use of flow reversal and a microbasket. N Engl J Med. 2002;347:769-70. [pmid: 12213956].
59 Mocco J, Tawk RG, Jahromi BS, et al. Endovascular intervention for acute thromboembolic stroke in young patients: An ideal population for aggressive intervention?. J Neurosurg. 2009;110:30-4. [pmid: 18821835].
60 Nesbit GM, Luh G, Tien R, Barnwell SL. New and future endovascular treatment strategies for acute ischemic stroke. J Vasc Interv Radiol. 2004;15:S103-10. [pmid: 15101519].
61 Newman CB, Pakbaz RS, Nguyen AD, et al. Endovascular treatment of extensive cerebral sinus thrombosis. J Neurosurg. 2009;110:442-5. [pmid: 18834264].
62 Nogueira RG, Schwamm LH, Buonanno FS, et al. Low-pressure balloon angioplasty with adjuvant pharmacological therapy in patients with acute ischemic stroke caused by intracranial arterial occlusions. Neuroradiology. 2008;50:331-40. [pmid: 18172631].
63 Noufal M, Schmidley JW, Erdem E, et al. Basilar artery occlusion treated with mechanical thrombectomy beyond eight hours with successful recanalization and good functional outcomes. Cerebrovasc Dis. 2009;27:614-5. [pmid: 19439931].
64 Olson SE, Pakbaz RS, Kerber CW. Rapid clot removal for acute stroke therapy: Technical case report. Neurosurgery. 2007;61:E86. [pmid: 17876223].
65 Oomura M, Hayakawa M, Sadato A, et al. Thrombectomy with soutenir for acute ischemic stroke patients unresponsive to intravenous recombinant tissue plasminogen activator. JNET. 2009;3:10-6.
66 Phillips S, Stanley L, Nicoletto H, et al. Use of emergency department transcranial doppler assessment of reperfusion after intravenous tPA for ischemic stroke. J Emerg Med. 2008. Epub ahead of print.
67 PPST Investigators. The penumbra pivotal stroke trial: Safety and effectiveness of a new generation of mechanical devices for clot removal in intracranial large vessel occlusive disease. Stroke. 2009;40:2761-8. [pmid: 19590057].
68 Qureshi AI, Janjua N, Kirmani JF, et al. Mechanical disruption of thrombus following intravenous tissue plasminogen activator for ischemic stroke: Clinical investigation study. J Neuroimaging. 2007;17:124-30. [pmid: 17441833].
69 Qureshi AI, Siddiqui AM, Kim SH, et al. Reocclusion of recanalized arteries during intra-arterial thrombolysis for acute ischemic stroke. Am J Neuroradiol. 2004;25:322-8. [pmid: 14970040].
70 Qureshi AI, Siddiqui AM, Suri MFK, et al. Aggressive mechanical clot disruption and low-dose intra-arterial third-generation thrombolytic agent for ischemic stroke: A prospective study. Neurosurgery. 2002;51:1319-29. [pmid: 12383381].
71 Schumacher HC, Meyers PM, Yavagal DR, et al. Endovascular mechanical thrombectomy of an occluded superior division branch of the left MCA for acute cardioembolic stroke. Cardiovasc Intervent Radiol. 2003;26:305-8. [pmid: 14562985].
72 Shah QA, Georgiadis A, Suri MFK, et al. Preliminary experience with intra-arterial nicardipine in patients with acute ischemic stroke. Neurocrit Care. 2007;7:53-7. [pmid: 17657656].
73 Smith WS, Sung G, Saver J, et al. Mechanical thrombectomy for acute ischemic stroke: Final results of the Multi MERCI trial. Stroke. 2008;39:1205-12. [pmid: 18309168].
74 Smith WS, Sung G, Starkman S, et al. Safety and efficacy of mechanical embolectomy in acute ischemic stroke: Results of the MERCI trial. Stroke. 2005;36:1432-8. [pmid: 15961709].
75 Struffert T, Köhrmann M, Engelhorn T, et al. Penumbra stroke system as an "add-on" for the treatment of large vessel occlusive disease following thrombolysis: First results. Eur Radiol. 2009;19:2286-93. [pmid: 19350248].
76 Sugrue PA, Hage ZA, Surdell DL, et al. Basilar artery occlusion following C1 lateral mass fracture managed by mechanical and pharmacological thrombolysis. Neurocrit Care. 2008:1-6.
77 Suzuki S, Kidwell CS, Starkman S, et al. Use of multimodal MRI and novel endovascular therapies in a patient ineligible for intravenous tissue plasminogen activator. Stroke. 2005;36:e77-9. [pmid: 16051897].
78 Tarr R, Alfke K, Stingele R, et al. Initial post-market experience of the penumbra system: Revascularization of large vessel occlusion in acute ischemic stroke in the united states and europe. Stroke. 2009;40:e151.
79 Tomsick T, Broderick J, Carrozella J, et al. Revascularization results in the interventional management of stroke II trial. AJNR Am J Neuroradiol. 2008;29:582-7. [pmid: 18337393].
80 Tsivgoulis G, Horton JA, Ness JM, et al. Intravenous thrombolysis followed by intra-arterial thrombolysis and mechanical thrombectomy for the treatment of pediatric ischemic stroke. J Neurol Sci. 2008;275:151-3. [pmid: 18722630].
81 Versnick EJ, Do HM, Albers GW, et al. Mechanical thrombectomy for acute stroke. Am J Neuroradiol. 2005;26:875-9. [pmid: 15814937].
82 Wikholm G. Transarterial embolectomy in acute stroke. Am J Neuroradiol. 2003;24:892-4. [pmid: 12748090].
83 Wikholm G. Mechanical intracranial embolectomy. Interv Neuroradiology. 1998;4:159-64.
84 Yin NS, Benavides S, Starkman S, et al. Autopsy findings after intracranial thrombectomy for acute ischemic stroke: A clinicopathologic study of 5 patients. Stroke. 2010;41:938-47. [pmid: 20360544].
85 Yu W, Binder D, Foster-Barber A, et al. Endovascular embolectomy of acute basilar artery occlusion. Neurology. 2003;61:1421-3. [pmid: 14638968].
86 Zaidat OO, Tolbert M, Smith TP, et al. Primary endovascular therapy with clot retrieval and balloon angioplasty for acute basilar artery occlusion. Pediatr Neurosurg. 2005;41:323-7. [pmid: 16293952].
87 Zhang A, Collinson RL, Hurst RW, et al. Rheolytic thrombectomy for cerebral sinus thrombosis. Neurocrit Care. 2008;9:17-26. [pmid: 18250978].

## Citations for Excluded Reports

1 AbuRahma AF, Hayes JD, Deel JT, et al. Complications of diagnostic carotid/cerebral arteriography when performed by a vascular surgeon. Vasc Endovasc Surg. 2006;40:189-95.
2 Aburahma AF, Robinson PA, Short YS. Management options for post carotid endarterectomy stroke. J Cardiovasc Surg. 1996;37:331-6. [pmid: 8698774].
3 Ade-Ajayi N, Hall NJ, Liesner R, et al. Acute neonatal arterial occlusion: Is thrombolysis safe and effective?. J Pediatr Surg. 2008;43:1827-32. [pmid: 18926215].
4 Adovasio R, Visintin E. The subclavian-carotid bypass as a method for treating obstruction of the common carotid. Ann Ital Chir. discussion 250–1; Mar–Apr. 1999;70:247-50. [pmid: 10434458].
5 Agrawal D, Mahapatra AK, Mishra NK. Fusiform aneurysm of a persistent trigeminal artery. J Clin Neurosci. 2005;12:500-3. [pmid: 15925796].
6 Ahn JY, Han IB, Chung SS, et al. Endovascular thrombolysis and stenting of a middle cerebral artery occlusion beyond 6 hours post-attack: Special reference to the usefulness of diffusion-perfusion MRI. Neurol Res. 2006;28:881-5. [pmid: 17288750].
7 Alfke K, Janssens U. Endovascular intervention in cases of impending stroke. Journal fur Anasthesie und Intensivbehandlung. 2006;13:274.
8 Aljama Perez De La Lastra PJ, Garcia Villanueva A, Higuero Moreno F. Acute arterial obstruction. Angiologia. 1975;27:78-82. [pmid: 1119728].
9 AlKawi A, Kirmani JF, Nazli JN, et al. Management of recurrent cerebral arterial occlusion in a patient with cardiac decompensation. Neurocrit Care. 2007;6:139-45. [pmid: 17522797].
10 Anand N, Chan C, Wang NE. Cerebral venous thrombosis: A case report. J Emerg Med. 2009;36:132-7. [pmid: 17976768].
11 Anda T, Suyama K, Kawano T, et al. Shotgun pellet embolus in the cerebral circulation via the internal carotid artery in the neck; a case report. No Shinkei Geka. 1992;20:457-61. [pmid: 1570071].
12 Arboix A. Thrombolytic treatment in acute cerebral infarction. Neurol India. 2007;55:8-9. [pmid: 17272890].
13 Armonda RA. Rapid clot removal for acute stroke therapy: Technical case report - commentary. Neurosurgery. 2007;61.
14 Arnold M, Steinlin M, Baumann A, et al. Thrombolysis in childhood stroke: Report of 2 cases and review of the literature. Stroke. 2009;40:801-7. [pmid: 19118242].
15 Assadian A, Senekowitsch C, Assadian O, et al. Combined open and endovascular stent grafting of internal carotid artery fibromuscular dysplasia: Long term results. Eur J Vascular Surg. 2005;29:345-9.
16 Balzer K. Treatment of carotid stenosis: Carotid surgery or stent? in favor of operation. Herz. 2004;29:90-103. [pmid: 14968345].
17 Bang OY, Saver JL, Buck BH, et al. Impact of collateral flow on tissue fate in acute ischaemic stroke. J Neurol Neurosur PS. 2008;79:625-9.
18 Bang OY, Saver JL, Liebeskind DS, et al. Cholesterol level and symptomatic hemorrhagic transformation after ischemic stroke thrombolysis. Neurology. 2007;68:737-42. [pmid: 17182976].
19 Barreto AD, Albright KC, Hallevi H, et al. Thrombus burden is associated with clinical outcome after intra-arterial therapy for acute ischemic stroke. Stroke. 2008;39:3231-5. [pmid: 18772444].
20 Baumgartner RW, Georgiadis D, Nedeltchev K, et al. Stent-assisted endovascular thrombolysis versus intravenous thrombolysis in internal carotid artery dissection with tandem internal carotid and middle cerebral artery occlusion. Stroke. 2008;39:e27-e28. [pmid: 18162619].
21 Belkin M, Mackey WC, Pessin MS, et al. Common carotid artery occlusion with patent internal and external carotid arteries: Diagnosis and surgical management. J Vasc Surg. 1993;17:1019-28. [pmid: 8505780].
22 Berthet JP, Marty-Ané CH, Picard E, et al. Acute carotid artery thrombosis: Description of 12 surgically treated cases. Ann Vasc Surg. 2005;19:11-8. [pmid: 15714361].
23 Bhatt A, Vora NA, Thomas AJ, et al. Lower pretreatment cerebral blood volume affects hemorrhagic risks after intra–arterial revascularization in acute stroke. Neurosurgery. 2008;63:874-8. [pmid: 19005377].
24 Bicknell CD, Cheshire NJW. The relationship between carotid atherosclerotic plaque morphology and the embolic risk during endovascular therapy. Eur J Vasc Endovasc Surg. 2003;26:17-21. [pmid: 12819643].
25 Bielecki D, Goracy J, Lewandowski M, et al. Acute thrombosis during carotid artery stenting treated with percutaneous embolectomy in a patient resistant to heparin. Kardiol Pol. 2008;66:559-62. discussion 563. [pmid: 18537065].
26 Biggs KL, Chiou AC, Hagino RT, et al. Endovascular repair of a spontaneous carotid artery dissection with carotid stent and coils. J Vasc Surg. 2004;40:170-3. [pmid: 15218480].
27 Blanchi C, Ballard JL, Bergan JH, et al. Vascular reconstruction and major resection for malignancy. Arch Surg. 1999;134:P851-5.
28 Borioni R, Garofalo M, Actis Dato GM, et al. Kinking of internal carotid artery: Is it a risk factor for cerebro–vascular damage in patients undergoing cardiac surgery?. J Cardiovasc Surg. 1994;35:325-6. [pmid: 7929545].
29 Bose A, Jansen O. PS Trial Investigators. The penumbra system: A new generation of mechanical device for clot removal by aspiration and extraction in acute stroke. Stroke. 2007;38:603.
30 Brautaset NJ. Endovascular treatment in brain infarction. Tidsskr Nor Laegeforen. 2008;128:1074. [pmid: 18451898].
31 Brekenfeld C, Remonda L, Nedeltchev K, et al. Endovascular neuroradiological treatment of acute ischemic stroke: Techniques and results in 350 patients. Neurol Res. 2005;27.
32 Brekenfeld C, Schroth G, Mattle HP, et al. Stent placement in acute cerebral artery occlusion: Use of a self-expandable intracranial stent for acute stroke treatment. Stroke. 2009;40:847-52. [pmid: 19182080].
33 Brunner U, Schneider E, Largiader J, et al. Acute arterial occlusion: Surgical thrombectomy versus local fibrinolysis. Vasa-J Vascular Dis. 1986;15:158-61.
34 Bulsara KR. Advances in mechanical devices for the treatment of stroke in patients with diabetes and impaired glucose tolerance. J CardiometablSyndr. 2007;2:131-2.
35 Carrillo EH, Osborne DL, Spain DA, et al. Blunt carotid artery injuries: Difficulties with the diagnosis prior to neurologic event. J Trauma. 199;46:1120-5. [pmid: 10372637].
36 Chaikof EL, Campbell BE, Smith RB III, et al. Paradoxical embolism and acute arterial occlusion: Rare or unsuspected?. J Vasc Surg. 1994;20:377-84. [pmid: 8084029].
37 Chapot R, Houdart E, Rogopoulos A, et al. Thromboaspiration in the basilar artery: Report of two cases. AJNR Am J Neuroradiol. 2002;23:282-4. [pmid: 11847055].
38 Charvát F, Lacman J, Mašková J, et al. Mechanical embolectomy by means of the merci retriever in patients with acute occlusion of brain arteries. Cesk slov Neurol N. 2008;71:69-74.
39 Chen YJ, Chen WL, Tsai WC, Tsao YT. Sentinel central retinal artery occlusion: A forme fruste of idiopathic renal infarction. Am J Emerg Med. 2009;27:253.e1-2. [pmid: 19371552].
40 Choi JH, Bateman BT, Mangla S, et al. Endovascular recanalization therapy in acute ischemic stroke. Stroke. 2006;37:419-24. [pmid: 16373652].
41 Chun JY, Smith W, Van Halbach V, et al. Current multimodality management of infectious intracranial aneurysms. Neurosurgery. 2001;48:1203-14. [pmid: 11383721].
42 Ciostek P, Myrcha P, Grochowicz Ł, et al. Surgical treatment of common carotid artery occlusion by means of the cervical approach. Pol Przegl Chir. 2004;76:1231-44.
43 Cohen JE, Lylyk P, Ferrario A, et al. Carotid stent angioplasty: The role of cerebral protection devices. Neurol Res. 2003;25:162-8. [pmid: 12635516].
44 Comeaux ME, Harkrider WW. Color doppler imaging versus angiography in near–total occlusion of the internal carotid artery. J Vasc Technol. 1994;18:85-7.
45 Coward LJ, McCabe DJ, Ederle J, et al. Long-term outcome after angioplasty and stenting for symptomatic vertebral artery stenosis compared with medical treatment in the carotid and vertebral artery transluminal angioplasty study (CAVATAS): A randomized trial. Stroke. 2007;38:1526-30. [pmid: 17395869].
46 Coward L, Featherstone R, Brown MM. Percutaneous transluminal angioplasty and stenting for vertebral artery stenosis. Cochrane Database Syst Rev. 2005;(2):CD000516. [pmid: 15846607].
47 Cox MW, Whittaker DR, Martinez C, et al. Traumatic pseudoaneurysms of the head and neck: Early endovascular intervention. J Vasc Surg. 2007;46:1227-33. [pmid: 18154999].
48 Cryer PE, Kissane J. Multiple arterial occlusions in a young woman. Am J Med. 1975;59:837-43. [pmid: 1190255].
49 Dai C, Wang S, Zhang X, et al. Stent placement in acute cerebral artery occlusion. Stroke. 2009;40.
50 Davis SM, Donnan GA. Merci retriever does it work?. Stroke. 2006;37:1342-3.
51 Delgado MG, Gil A, Mateos V, et al. Perfusion computed tomography-guided subacute endovascular reperfusion in a patient with carotid occlusion. Ann Vasc Surg. 2008;22:465-8. [pmid: 18466823].
52 Deshmukh VR, Fiorella DJ, Albuquerque FC, et al. Intra-arterial thrombolysis for acute ischemic stroke: Preliminary experience with platelet glycoprotein IIb/IIIa inhibitors as adjunctive therapy. Neurosurgery. 2005;56:46-54. discussion 54–5. [pmid: 15617585].
53 DeVries JT, White CJ, Collins TJ, et al. Acute stroke intervention by interventional cardiologists. Catheter Cardio Inte. 2009;73:692-8.
54 Diederich KW, Tuebler T, Schuler G, et al. First clinical experience in 42 patients with the mo.ma device, a novel endovascular clamping system for prevention of embolic stroke during percutaneous carotid stenting. Am J Cardiol. 2002:TCT136.
55 Dorrler J, Maurer PC, Holzmann T, et al. Surgical treatment of acute arterial and venous occlusion. Hefte Unfallheilkd. 1984;164:383-9.
56 Duckwiler G. MERCI Trial Investigators. Results of the combined MERCI (mechanical embolus removal in cerebral ischemia) trials I–II. J Neurosurg. 2004;100:A180.
57 Ecker RD, Tummala RP, Levy EI, et al. "Internal cross-clamping" for symptomatic internal carotid artery thrombus: Report of two cases. J Neurosurg. 2007;107:1223-7. [pmid: 18077962].
58 Ederle J, Featherstone R, Brown MM. Percutaneous transluminal angioplasty and stenting for carotid artery stenosis. Cochrane Database Syst Rev. 2007;(4):CD000515. [pmid: 17943745].
59 Edgell RC, Yavagal DR, Agner C, et al. Recanalization of a symptomatic extracranial internal carotid artery near occlusion with proximal and distal protection: Technical case report. Neurosurgery. 2007;61:E174. [pmid: 17621010].
60 Egashira Y, Ikegame Y, Aki T, et al. Surgical treatment of a ruptured traumatic anterior cerebral artery aneurysm: Report of two cases. Jpn J Neurosurg. 2005;14:635-40.
61 Emanuelli G, Marina R, Bizzi U, et al. Endovascular therapy versus surgery in carotid stenosis: Personal experience. Ital J Vasc Endovasc. 2005;12:47-54.
62 Eskioglu E, Burry MV, Mericle RA. Transradial approach for neuroendovascular surgery of intracranial vascular lesions. J Neurosurg. 2004;101:767-9. [pmid: 15540914].
63 Fearn SJ, Parry AD, Picton AJ, et al. Should heparin be reversed after carotid endarterectomy? A randomised prospective trial. Eur J Vasc Endovasc. 1997;13:394-7.
64 Feist RM, Emond TL. Translumenal nd:Yag laser embolysis for central retinal artery occlusion. Retina. 2005;25:797-9. [pmid: 16141875].
65 Feiwell RJ, Besmertis L, Sarkar R, et al. Detection of clinically silent infarcts after carotid endarterectomy by use of diffusion-weighted imaging. Am J Neuroradiol. 2001;22:646-9. [pmid: 11290471].
66 Felberg RA, Burgin WS, Shaw S, et al. Patients who received thrombolysis for acute stroke and required mechanical ventilation: Outcome and analysis. Stroke. 2000;31:138.
67 Feng W, Caplan M, Matheus MG, et al. Meningovascular syphilis with fatal vertebrobasilar occlusion. Am J Med Sci. 2009;338:169-71. [pmid: 19680027].
68 Fiehler J, Boor S, Dörbecker R, et al. Table for optimization and monitoring of cerebral aneurysm therapy (TOMCAT): Results and implications of the lead-in phase. Clin Neuroradiol. 2008;18:168-76.
69 Findlay JM, Ashforth R, Dean N. "Malignant" carotid artery dissection. Can J Neurol Sci. 2002;29:378-85. [pmid: 12463495].
70 Findlay JM, Lougheed WM, Hamilton MG, et al. Carotid microendarterectomy. Neurosurgery. 1993;32:792-8. [pmid: 8492854].
71 Flint AC, Duckwiler GR, Budzik RF, et al. MERCI and Multi MERCI Writing Committee. Mechanical thrombectomy of intracranial internal carotid occlusion: Pooled results of the MERCI and multi MERCI part I trials. Stroke. 2007;38:1274-80. [pmid: 17332445].
72 Gada HG, Ali MJ, Graziano K, et al. Carotid embolectomy in the treatment of a paradoxical embolus. Ann Vasc Surg. 2003;17:456-60. [pmid: 14670027].
73 Gagliardi R, Benvenuti L, Guizzardi G. Acute operation in cases of middle cerebral artery occlusion. Neurosurgery. 1983;12:636-9. [pmid: 6877545].
74 Gandini R, Spinelli A, Fabiano S, et al. Carotid artery stenting with filter protection in high-risk patients showing severe electroencephalographic alterations during carotid endarterectomy. J Endovasc Surg. 2006;13:451-6.
75 Gansera B, Schmidtler F, Angelis I, et al. Simultaneous carotid endarterectomy and cardiac surgery-additional risk factor or safe procedure?. Z Kardiol. 2004;93:49-57. [pmid: 14740241].
76 Gao Z, Miao Z, Ling F. Correlation of risk factors and therapeutic options with the unfavorable results in young patients with intra- and extracranial artery stenosis. Chinese Journal of Cerebrovascular Diseases. 2008;5:10-4.
77 García-Arumí J, Martinez-Castillo V, Boixadera A, et al. Surgical embolus removal in retinal artery occlusion. Br J Ophthalmol. 2006;90:1252-5. [pmid: 16854826].
78 Georgiadis AL, Hussein HM, Wright EJ, et al. Current statin use is associated with higher recanalization rates among patients treated with endovascular procedures for acute ischemic stroke. Stroke. 2007;38:506.
79 Gibbons RJ, Miller TD. Tc-99m sestamibi infarct size as a surrogate endpoint. J Nucl Cardiol. 2005;12:12-9. [pmid: 15682361].
80 Gobin A. Result of the MERCI (mechanical embolus removal in cerebral ischemia) trial. Am J Cardiol. 2004;94(Suppl1):128E.
81 Goldstein LB. Acute ischemic stroke treatment in 2007. Circulation. 2007;116:1504-14. [pmid: 17893286].
82 Gomez-Beldarrain M, Telleria M, Garcia -Monco JC. Peripheral arterial embolism during thrombolysis for stroke. Neurology. 2006;67:1096-7. [pmid: 17000990].
83 Green DW, Sanchez LA, Parodi JC, et al. Acute thromboembolic events during carotid artery angioplasty and stenting: Etiology and a technique of neurorescue. J Endovasc Ther. 2005;12:360-5. [pmid: 15943512].
84 Greiner C, Wassmann H, Palkovic S, et al. Revascularization procedures in internal carotid artery pseudo-occlusion. Acta Neurochir. 2004;146:237-43. [pmid: 15015045].
85 Grigoriadis S, Gomori JM, Grigoriadis N, et al. Clinically successful late recanalization of basilar artery occlusion in childhood: What are the odds? case report and review of the literature. J Neurol Sci. 2007;260:256-60. [pmid: 17482211].
86 Grobelny TJ, Akhtar N, Rymer M, et al. Intracranial thrombolysis outcome analysis in the mechanical embolus removal in cerebral ischemia (MERCI) trial. J Neurosurg. 2004;100:A191-2.
87 Gross BA, Hurley MC, Bernstein R, et al. Endovascular recanalization for subacute symptomatic intracranial arterial occlusion: A report of two cases. ClinNeurol Neurosurg. 2008;110:1058-63.
88 Gubitz G, Lip G, Sudlow C, et al. Secondary prevention of stroke. Vasa-J Vascular Dis. 2004;33:110-4.
89 Hagendorff A, Hertfelder HJ, Fehske W, et al. Recurrent arterial thromboembolism in hereditary hypoplasminogenaemia. Dtsch Med Wochenschr. 1996;121:263-8. [pmid: 8681773].
90 Halse O, Clifton A, Cloud GC. Endovascular intervention for symptomatic bilateral carotid artery stenosis in an octogenarian. Age Ageing. 2007;36:102-4. [pmid: 17114199].
91 Hamann GF. PTCA and STENT in acute brain infarction. Internist. 1999;40:1333. [pmid: 10642921].
92 Hankey GJ. The BASICS of treating symptomatic basilar artery thrombosis. Lancet Neurol. 2009;8:695-7. [pmid: 19577963].
93 Hanoa R. Carotid surgery for the prevention of stroke. Tidsskr Nor Laegeforen. 2003;123:767. [pmid: 12693109].
94 Hellier KD, Hampton JL, Guadagno JV, et al. Perfusion CT helps decision making for thrombolysis when there is no clear time or onset. J Neurol Neurosur PS. 2006;77:417-9.
95 Hepgul KT, Canbolat AT, Hamamcioglu MK, et al. Microsurgical removal of a balloon embolus from the middle cerebral artery caused during endovascular treatment of carotid-cavernous fistula: Case report. Turkish Neurosurgery. 1994;4:88-92.
96 Higashida RT. Recent advances in the interventional treatment of acute ischemic stroke. Cerebrovasc Dis. 2005;20:140-7. [pmid: 16327265].
97 Hirschl M, Kundi M, Blazek G. Five-year follow-up of patients after thromboendarterectomy of the internal carotid artery: Relevance of baroreceptor sensitivity. Stroke. 1996;27:1167-72. [pmid: 8685922].
98 Ho J, Mah JK, Hill MD, Pacaud D. Pediatric stroke associated with new onset type 1 diabetes mellitus: Case reports and review of the literature. Pediatr Diabetes. 2006;7:116-21. [pmid: 16629718].
99 Hoh DJ, Larsen DW, Elder JB, et al. Novel use of an endovascular embolectomy device for retrograde suction decompression-assisted clip ligation of a large paraclinoid aneurysm: Technical case report. Neurosurgery. 2008;62:ONSE412-3. discussion ONSE 413–4. [pmid: 18596535].
100 Horiuchi T, Nitta J, Sakai K, et al. Emergency embolectomy for treatment of acute middle cerebral artery occlusion. JNeurosurg. 2007;106:257-62. [pmid: 17410709].
101 Huang Y, Chen Y, Wang Y, et al. Cervicocranial arterial dissection: Experience of 73 patients in a single center. Surg Neurol. 2009;72(S2):20-7. [pmid: 19559924].
102 Hulusi M, Basaran M, Yilmaz AT. Carotid and coronary artery occlusion in a patient with takayasu arteritis. J Card Surg. 2007;22:352-5. [pmid: 17661784].
103 Inagaki T, Saito K, Okuyama T, et al. Indication of thrombolysis for middle cerebral artery occlusion using MR diffusion -weighted image. Interv Neuroradiol. 1999;5:137-44. [pmid: 20670555].
104 Iskander A, Nayak A, Chauhan MS. Submassive pulmonary embolism and paradoxical embolic stroke treated with percutaneous rheolytic thrombectomy and closure of the patent foramen ovale. Catheter Cardio Inte. 2005;64:356-60.
105 Iwata T, Mori T, Tajiri H. Successful removal of clots embolic carotid occlusion by aspiration with a syringe –case report. Brain Nerve. 2008;60:1067-72. [pmid: 18807941].
106 Jacobsen EA. Stroke--endovascular treatment methods. Tidsskr Nor Laegeforen. 2008;128:698-702. [pmid: 18337851].
107 Jacobson JH II, Wallman LJ, Schumacher GA. Microsurgery as an aid to middle cerebral artery endarterectomy. Microsurgery. 1992;13:112-8. [pmid: 1598079].
108 Janjua N, Alkawi A, Suri MF, et al. Impact of arterial reocclusion and distal fragmentation during thrombolysis among patients with acute ischemic stroke. AJNR Am J Neuroradiol. 2008;29:253-8. [pmid: 18024576].
109 Jicking G, Scozzafava J, Mouradian M, et al. A cool-handed patient with a right hemispheric stroke. Can J Neurol Sci. 2008;35:655-7. [pmid: 19235453].
110 Johnston SC, Hauser SL. Neurology and medical devices. Ann Neurol. 2006;60.
111 Josephson SA, Saver JL, Smith WS. Comparison of mechanical embolectomy and intraarterial thrombolysis in acute ischemic stroke within the MCA: MERCI and multi MERCI compared to PROACT II. Neurocrit Care. 2009;10:43-9. [pmid: 19030784].
112 Jost JO, Ruehland D, Pircher W. Acute arterial occlusion. Z Allgemeinmed. 1981;57:765-71.
113 Jung YA, In BH, Sang SC, et al. Endovascular thrombolysis and stenting of a middle cerebral artery occlusion beyond 6 hours post-attack: Special reference to the usefulness of diffusion-perfusion MRI. Neurol Res. 2006;28:881-5. [pmid: 17288750].
114 Kai Y, Hamada J, Morioka M, et al. Successful treatment of a ruptured dissecting basilar artery aneurysm: Case report. J Neurosurg. 2004;100:1072-5. [pmid: 15200123].
115 Kakinuma K, Ezuka I, Takai N, et al. The simple indicator for revascularization of acute middle cerebral artery occlusion using angiogram and ultra-early embolectomy. Surg Neurol. 1999;51:332-41. [pmid: 10086500].
116 Kakinuma K, Ezuka I, Takai N, et al. The simple indicator for revascularization of acute middle cerebral artery occlusion using angiogram and ultra-early embolectomy. Surg Neurol. 1999;51:332-41. [pmid: 10086500].
117 Kao HL, Lin MS, Wang CS, et al. Feasibility of endovascular recanalization for symptomatic cervical internal carotid artery occlusion. J Am Coll Cardiol. 2007;49:765-71. [pmid: 17306705].
118 Kao H, Lin M. Feasibility ad safety of endovascular recanalization for chronic cervical internal carotid artery occlusion. Am J Cardiol. 2008;102(Suppl1):103I.
119 Karam C, Koussa S. Cerebral dural sinus thrombosis following cisplatin chemotherapy. J Clin Neurosci. 2008;15:1274-5. [pmid: 18824357].
120 Kelly ME, Furlan AJ, Fiorella D. Recanalization of an acute middle cerebral artery occlusion using a self-expanding, reconstrainable, intracranial microstent as a temporary endovascular bypass. Stroke. 2008;39:1770-3. [pmid: 18388338].
121 Kidwell C, Jahan R, Starkman S, et al. Merci retriever and recanalization of stroke clots using embolectomy. International Stroke Conference 2009(Ongoing Clinical Trials Abstract). 2009.
122 Kidwell CS. Embolectomy for clot removal after acute stroke. Cochrane Central Register of Controlled Trials. 2005:CN-00603486.
123 Kidwell CS, Jahan R, Starkman S, et al. MR and REcanalization of stroke clots using embolectomy (MR RESCUE). International Stroke Conference. 2006. Ongoing Clinical Trials Abstracts. 2006.
124 Kidwell CS, Jahan R, Starkman S, et al. MR and recanalization of stroke clots using embolectomy (MR RESCUE). International Stroke Conference. 2005. Ongoing Clinical Trials Abstracts. 2005.
125 Kidwell CS, Saver JL, Latour LL, et al. Reduced incidence of HARM following mechanical thrombectomy compared to intra-arterial thrombolysis in acute stroke. Stroke. 2004;35:236.
126 Kim DJ, Kim DI, Byun JS, et al. Simple microwire and microcatheter mechanical thrombolysis with adjuvant intraarterial urokinase for treatment of hyperacute ischemic stroke patients. Acta Radiol. 2008;49:351-7. [pmid: 18365826].
127 Kim I, Inada Y, Kim F. Surgical treatment of extracranial internal carotid occulusion. A case of thrombo-endarterectomy using fogarty catheter. Neurol Surg Tokyo. 1978;6:913-7.
128 Kirton A, Wong JH, Mah J, et al. Successful endovascular therapy for acute basilar thrombosis in an adolescent. Pediatrics. 2003;112:e248-51. [pmid: 12949321].
129 Klisch J. Acute simultaneous occlusion of the distal common carotid artery and middle cerebral artery: Endovascular recanalization. Klinische Neuroradiologie. 2004;14:216-22.
130 Kniemeyer HW, Aulich A, Schlachetzki F, et al. Pseudo-and segmental occlusion of the internal carotid artery: A new classification, surgical treatment and results. Eur J Vasc Endovasc. 1996;12:310-20.
131 Kobayashi M, Takayama H, Mihara B, et al. Severe vasospasm caused by repeated intraventricular haemorrhage from small arteriovenous malformation. Acta Neurochir. 2002;144:405-6. [pmid: 12021892].
132 Koch P, Desal HA, Auffray-Calvier E, et al. Natural history and management of mycotic intracranial aneurysm. J Neuroradiology. 2005;32:258-65.
133 Koenigsberg RA, Gul N, Thomas C, et al. Emergency treatment of anterior circulation cerebral arterial thrombosis within the 6-to 9 -h window. Emer Radiol. 2000;7:129-34.
134 Koide M, Abe M, Kodera K, et al. Thromboembolism originated from the pulmonary artery stump after fontan operation. Jpn J Thorac Cardiovasc Surg. 1999;47:346-9. [pmid: 10481395].
135 Kole MK, Pelz DM, Lee DH, et al. Intra-arterial thrombolysis of embolic middle cerebral artery using collateral pathways. Can J Neurol Sci. 2005;32:257-60. [pmid: 16018166].
136 Kollár L, Kasza G, Rozsos I, et al. Internal carotid stent implantation with angioscopic control. Acta Chir Hung. 1997;36:168-9. [pmid: 9408332].
137 Konovalov AN, Serbinenko FA. A case of successful removal of a middle cerebral artery thrombus developing after occlusion with balloons of the afferent vessels of an arteriovenous aneurysm (russian). Zhurnal Voprosy Nejrokhirurgii Imeni NNBurdenko. 1973;37:29-34.
138 Koren MJ, Bryant B, Hilton TC, et al. Atherosclerotic disease of the aortic arch and the risk of ischemic stroke. N Engl J Med. 1995;332:1237-8. [pmid: 7755771].
139 Krajina A, Kraji kova D, Špriňar Z, et al. Mechanical percutaneous extraction of embolus in acute stroke: A case report and review of the literature. Ceska a Slovenska Neurologie a Neurochirurgie. 2005;68:51-7.
140 Kraus GE, Herman JM, Marciano F, et al. Ruptured giant aneurysm of an occluded middle cerebralartery in a severe - grade patient: Case report. Neurosurgery. 1995;36:169-72. [pmid: 7708154].
141 LaMuraglia GM, Fabian RL, Brewster DC, et al. The current surgical management of carotid body paragangliomas. J Vasc Surg. 1992;15:1038-45. [pmid: 1597886].
142 Lanfranconi S, Bersano A, D'Adda E, et al. Safety of carotid stenting for stroke prevention: Need of an independent outcome assessor. Neurol Sci. 04. 2009;30:93-7. [pmid: 19189045].
143 Lawton MT, Quinones-Hinojosa A, Chang EF, et al. Thrombotic intracranial aneurysms: Classification scheme and management strategies in 68 patients. Neurosurgery. 2005;56:441-54. [pmid: 15730569].
144 Le BHC, Williams DS, Gibbs P. Acute arterial ischaemia secondary to multiple tumour emboli. Intern Med J. 2006;36:475-6. [pmid: 16780462].
145 Leary MC, Gobin YP, Jahan R, et al. Thrombolysis following attempted mechanical embolectomy in acute stroke treatment (MERCI trial). Stroke. 2003;34:311.
146 Leary MC, Saver JL, Gobin YP, et al. Beyond tissue plasminogen activator: Mechanical intervention in acute stroke. Ann Emerg Med. 2003;41:838-46. [pmid: 12764340].
147 Lee VH, Samuels S, Herbst TJ, et al. Histopathologic description of wingspan stent in acute ischemic stroke. Neurocrit Care. 2009. [doi: 10.1007/s12028-009-9258-0].
148 Leischker AH, Kolb G. Patients over 75 with symptomatic carotid stenosis profit more from carotid thromboendarterectomy than younger patients. European Journal of Geriatrics. 2001;3:205-7.
149 Levy EI, Ecker RD, Hanel RA, et al. Acute M2 bifurcation stenting for cerebral infarction: Lessons learned from the heart: Technical case report. Neurosurgery. 2006;58.
150 Liebeskind D, Duckwiler G, Starkman S, et al. No reflow: Open arteries without tissue perfusion in acute ischemic stroke. Stroke. 2009;40:e122.
151 Lilja A, Holtås S. Nya tekniker för säker diagnos och terapi vid stroke. Lakartidningen. 2008;105:3424-9. [pmid: 19112972].
152 Lin M, Kao H. Safety of endovascular recanalization for symptomatic cervical internal carotid artery occlusion. Am J Cardiol. 2008:AS221.
153 Lin M, Wang C, Lin L, et al. Feasibility and safety of endovascular recanalization for symptomatic cervical internal carotid artery occlusion. Circulation. 2006;114:684-5.
154 Lin PH, Bush RL, Peden E, et al. What is the learning curve for carotid artery stenting with neuroprotection? analysis of 200 consecutive cases at an academic institution. Perspect Vasc Surg Endovasc Ther. 2005;17:113-25. [pmid: 16110374].
155 Lin PH, Bush RL, Peden EK, et al. Carotid artery stenting with neuroprotection: Assessing the learning curve and treatment outcome. Am J Surg. 2005;190:850-7. [pmid: 16307933].
156 Lin PH, Kougias P, Huynh TT, et al. Endovascular repair of ascending aortic pseudoaneurysm: Technical considerations of a common carotid artery approach using the zenith aortic cuff endograft. J Endovasc Ther. 2007;14:794-8. [pmid: 18052591].
157 Linfante I, Llinas RH, Selim M, et al. Clinical and vascular outcome in internal carotid artery versus middle cerebral artery occlusions after intravenous tissue plasminogen activator. Stroke. 2002;33:2066-71. [pmid: 12154264].
158 Linskey ME, Sekhar LN, Hecht ST. Emergency embolectomy for embolic occlusion of the middle cerebral artery after internal carotid artery balloon test occlusion. case report. J Neurosurg. 1992;77:134-8. [pmid: 1607954].
159 Linskey ME, Stephanian E, Sekhar LN. Emergent middle cerebral artery embolectomy: A useful technique for cranial base surgery. Skull Base Surg. 1993;3:80-6. [pmid: 17170894].
160 Lord RSA, Raj TB, Stary DL, et al. Comparison of saphenous vein patch, polytetrafluoroethylene patch, and direct arteriotomy closure after carotid endarterectomy. part I. perioperative results. J Vasc Surg. 1989;9:521-9. [pmid: 2709521].
161 Lovblad KO. Intracerebral interventions other than lysis in acute stroke. Cardiovasc Intervent Radiol. 2005;28.
162 Lutsep HL, Clark WM, Nesbit GH, et al. Intra-arterial suction thrombectomy in acute stroke. Stroke. 1999;30:P13.
163 Lutsep HL, Clark WM, Nesbit GM, et al. Intraarterial suction thrombectomy in acute stroke. Am J Neuroradiol. 2002;23:783-6. [pmid: 12006277].
164 Lutsep HL, Rymer MM, Nesbit GM. Vertebrobasilar revascularization rates and outcomes in the MERCI and multi-MERCI trials. J Stroke Cerebrovasc Dis. 2008;17:55-7. [pmid: 18346645].
165 Mangiafico S, Cellerini M, Nencini P, et al. Intravenous glycoprotein IIb/IIIa inhibitor (tirofiban) followed by intra-arterial urokinase and mechanical thrombolysis in stroke. AJNR Am J Neuroradiol. 2005;26:2595-601. [pmid: 16286408].
166 Mangiafico S, Cellerini M, Nencini P, et al. Intravenous tirofiban with intra-arterial urokinase and mechanical thrombolysis in stroke: Preliminary experience in 11 cases. Stroke. 2005;36:2154-8. [pmid: 16141418].
167 Marder V, Chute D, Starkman S, et al. Histology of thrombi retrieved from acute ischemic stroke patients by endovascular embolectomy. Stroke. 2005;36:516.
168 Marder VJ, Chute DJ, Starkman S, et al. Analysis of thrombi retrieved from cerebral arteries of patients with acute ischemic stroke. Stroke. 2006;37:2086-93. [pmid: 16794209].
169 Martinez H, Zoarski GH, Obuchowski AM, et al. Mechanical thrombectomy of the internal carotid artery and middle cerebral arteries for acute stroke by using the retriever device. Am J Neuroradiol. 2004;25:1812-5. [pmid: 15569753].
170 Martínez-Fernández E, González García A, Gil Peralta A, et al. Outcome of intraarterial procedures in acute ischemic stroke. Neurologia. 2008;23:21-8. [pmid: 18365776].
171 Massano J, Ferreira D, Toledo T, et al. Stroke and multiple peripheral thrombotic events in an adult with varicella. EurJ Neurol. 2008;15:e90-1. [pmid: 18717719].
172 Mazighi M, Serfaty J-, Labreuche J, et al. Comparison of intravenous alteplase with a combined intravenous-endovascular approach in patients with stroke and confirmed arterial occlusion (RECANALISE study): A prospective cohort study. Lancet Neurol. 2009;8:802-9. [pmid: 19647488].
173 McCormick PW, Spetzler RF, Bailes JE, et al. Thromboendarterectomy of the symptomatic occluded internal carotid artery. J Neurosurg. 1992;76:752-8. [pmid: 1564537].
174 McKinney WB, O'Hara W, Sreeram K, et al. The successful surgical treatment of a paradoxical embolus to the carotid bifurcation. J Vasc Surg. 2001;33:880-2. [pmid: 11296346].
175 McLaughlin MR, Jho H, Kwon Y. Acute subdural hematoma caused by a ruptured giant intracavernous aneurysm: Case report. Neurosurgery. 1996;38:388-92. [pmid: 8869069].
176 Meyer FB. Emergency embolectomy for treatment of acute middle cerebral artery occlusion. J Neurosurg. 2007;106:255. [pmid: 17436469].
177 Meyer FB, Friedman JA, Nichols DA, et al. Surgical repair of clinoidal segment carotid artery aneurysms unsuitable for endovascular treatment. Neurosurgery. 2001;48:476-86. [pmid: 11270536].
178 Meyer FB, Piepgras DG, Sundt TM Jr, et al. Emergency embolectomy for acute occlusion of the middle cerebral artery. J Neurosurg. 1985;62:639-47. [pmid: 3989586].
179 Mohammad Y, Hussein HM, Christoforidis G, et al. The effect of mechanical disruption of thrombus during intra-arterial thrombolysis for patients with acute ischemic stroke. Neurology. 2008;70(Suppl1):A358.
180 Morgan T, Zuccarello M, Narayan R, et al. Preliminary findings of the minimally-invasive surgery plus rtPA for intracerebral hemorrhage evacuation (MISTIE) clinical trial. Act Neur S. 2008;105:147-51.
181 Mudra H, Ziegler M, Haufe MC, et al. Percutaneous carotid angioplasty with stent implantation and protection device against embolism--a prospective study of 100 consecutive cases. Dtsch Med Wochenschr. 2003;128:790-6. [pmid: 12690572].
182 Mullen MT, Sansing LH, Hurst RW, et al. Obstructive hydrocephalus from venous sinus thrombosis. Neurocrit Care. 2009;10:359-62. [pmid: 18542853].
183 Müllges W. Acute cerebral ischemia and its treatment. Journal fur Anasthesie und Intensivbehandlung. 2007:14.
184 Muramoto M, Kim F, Kim I. Thrombectomy of the middle cerebral artery. Neurol Surg Tokyo. 1981;9:733-8.
185 Mussa FF, Aaronson N, Lamparello PJ, Maldonado TS, Cayne NS, Adelman MA, et al. Outcome of carotid endarterectomy for acute neurological deficit. Vasc Endovasc Surg. 2009;43:364-9.
186 Myers SI, Valentine RJ, Estrera A, et al. The intra-aortic balloon pump, a novel addition to staged repair of combined symptomatic cerebrovascular and coronary artery disease. Ann Vasc Surg. 1993;7:239-42. [pmid: 8318387].
187 Nagaraja D, Sarma GRK. Treatment of cerebral sinus/venous thrombosis. Neurol India. 2002;50:114-6. [pmid: 12134170].
188 Nakamura K, Murata K, Kawakami T, et al. Percutaneous transluminal angioplasty for stenosis of the posterior cerebral artery in progressive stroke -case report. Neurol Med. 2009;49:351-3.
189 Nanjudappa A, Dieter RS. How would you treat this patient?. VDM. 2008;5:96.
190 Natali J. The surgical treatment of stenoses and occlusions of the internal carotid artery. Ann Chir. 1973;27:297-304. [pmid: 4707145].
191 Nazliel B, Starkman S, Liebeskind D, et al. Impact of endovascular recanalization upon functional outcome in acute ischemic stroke. Neurology. 2007;68:A88.
192 Nedeltchev K, Brekenfeld C, Remonda L, et al. Internal carotid artery stent implantation in 25 patients with acute stroke: Preliminary results. Radiology. 2005;237:1029-37. [pmid: 16237137].
193 Nemati MN, Dietz H. Regional cerebral blood circulation and cerebrovascular reserve capacity as indications for in vascular reconstructive surgery. Fortschr Neurol Psychiatr. 1996:515-21. [pmid: 9053392].
194 Nikas D, Reimers B, Elisabetta M, et al. Percutaneous interventions in patients with acute ischemic stroke related to obstructive atherosclerotic disease or dissection of the extracranial carotid artery. J Endovasc Ther. 2007;14:279-88. [pmid: 17723015].
195 Nogueira RG, Smith WS. Safety and efficacy of endovascular thrombectomy in patients with abnormal hemostasis pooled analysis of the MERCI and multi MERCI trials. Stroke. 2009;40:516-22. [pmid: 19095994].
196 Nogueira RG, Liebeskind DS, Smith WS. Systolic blood pressure is a strong predictor of vessel recanalization in acute ischemic stroke patients undergoing thrombectomy: Pooled analysis of the MERCI and multi MERCI trials. Neurology. 2009;72(Suppl3):A4.
197 Nogueira RG, Lielbeskind DS, Sung G, et al. MERCI Multi MERCI Writing Comm. Predictors of clinical outcomes in acute ischemic stroke patients undergoing thrombectomy: Pooled analysis of the MERCI and multi MERCI trials. Stroke. 2009;40:E131.
198 Nowierski LW Jr. Embolectomy following major artery occlusion. Northwest Med. 1956;55:955-8. [pmid: 13358971].
199 Ohanian AG, Saver JL, Starkman S, et al. Successful endovascular recanalization predicts modest reduction of reactive hypertension in acute ischemic stroke. Stroke. 2008;39:725-6.
200 Opremcak E, Rehmar AJ, Ridenour CD, et al. Restoration of retinal blood flow via translumenal nd:YAG embolysis/embolectomy (TYL/E) for central and branch retinal artery occlusion. Retina. 2008;28:226-35. [pmid: 18301027].
201 Ozdemir O, Bussière M, Leung A, et al. Intra-arterial thrombolysis of occluded middle cerebral artery by use of collateral pathways in patients with tandem cervical carotid artery/middle cerebral artery occlusion. Am J Neuroradiol. 2008;29:1596-600. [pmid: 18524975].
202 Panagotacos JJ, Bang OY, Saver JL, et al. Multimodal MRI predicts outcome of mechanical thrombectomy for acute cerebral ischemia. Ann Neurol. 2008;64(Suppl12):S18.
203 Parodi JC, Rubin BG, Azizzadeh A, et al. Endovascular treatment of an internal carotid artery thrombus using reversal of flow: A case report. J Vasc Surg. 2005;41:146-50. [pmid: 15696059].
204 Patel RK, Fasan O, Arya R. Thrombolysis in pregnancy. Thromb Haemost. 2003;90:1216-7. [pmid: 14652661].
205 Patil CG, Long EF, Lansberg MG. Cost-effectiveness analysis of mechanical thrombectomy in acute ischemic stroke. J Neurosurg. 2009;110:508-13. [pmid: 19025358].
206 Peiper C, Nowack J, Ktenidis K, et al. Eversion endarterectomy versus open thromboendarterectomy and patch plasty for the treatment of internal carotid artery stenosis. Eur J Vasc Endovasc. 1999;18:339-43.
207 Peterson BG, Resnick SA, Morasch MD, et al. Aortic arch vessel stenting: A single-center experience using cerebral protection. Arch Surg. 2006;141:560-3. [pmid: 16785356].
208 Peyman GA, Gremillion CM Jr. Surgical removal of a branch retinal artery embolus: A case report. Int Ophthalmol. 1990;14:295-8. [pmid: 2370131].
209 Pfefferkorn T, Mayer TE, Dichgans M. Telephone-guided intravenous thrombolysis followed by mechanical recanalisation therapy for acute basilar artery occlusion. J Neurol. 2007;254(Suppl3):52.
210 Pfefferkorn T, Mayer TE, Opherk C, et al. Staged escalation therapy in acute basilar artery occlusion: Intravenous thrombolysis and on-demand consecutive endovascular mechanical thrombectomy: Preliminary experience in 16 patients. Stroke. 2008;39:1496-500. [pmid: 18323481].
211 Prabhakaran S, Chen M, Choi JH, et al. Major neurologic improvement following endovascular recanalization therapy for acute ischemic stroke. Cerebrovasc Dis. 2008;25:401-7. [pmid: 18349533].
212 Pride GL Jr, Horowitz MB, Purdy PD. Endovascular problem solving with intravascular stents. Am J Neuroradiol. 2000;21:532-40. [pmid: 10730647].
213 Qureshi AI, Alkawi A, Hussein HM, et al. Angiographic analysis of intravascular thrombus volume in patients with acute ischemic stroke. J Endovasc Ther. 2007;14:475-82. [pmid: 17696621].
214 Qureshi AI, Kirmani JF, Janjua N, et al. Mechanical thrombectomy following intravenous thrombolysis for ischemic stroke is safe and promotes recanalization. Stroke. 2006;37:658.
215 Reimers B, Tübler T, De Donato G, et al. Endovascular treatment of in-stent restenosis after carotid artery stenting: Immediate and midterm results. J Endovasc Ther. 2006;13:429-35. [pmid: 16928155].
216 Restrepo L, Bang OY, Ovbiagele B, et al. Impact of hyperlipidemia and statins on ischemic stroke outcomes after intra-arterial fibrinolysis and percutaneous mechanical embolectomy. Cerebrovasc Dis. 2009;28:384-90. [pmid: 19713698].
217 Restrepo L, Bang OY, Ovbiagele B, et al. Safety and potential benefits of statins in stroke patients undergoing intra-arterial thrombolysis and percutaneous mechanical embolectomy. Stroke. 2008;39:691.
218 Reynard M, Hanscom TA. Neodymium:Yttrium-aluminum-garnet laser arteriotomy with embolectomy for central retinal artery occlusion. Am J Ophthalmol. 2004;137:196-8. [pmid: 14700675].
219 Ringer AJ, Qureshi AI, Fessler RD, et al. Angioplasty of intracranial occlusion resistant to thrombolysis in acute ischemic stroke. Neurosurgery. 2001;48:1282-90. [pmid: 11383731].
220 Rose SC. Mechanical devices for arterial occlusion and therapeutic vascular occlusion utilizing steel coil technique: Clinical applications. Am J Roentgenol. 2009;192:321-4. [pmid: 19155388].
221 Russman AN, Frost N, Katzan IL, et al. Antithrombotic therapy and thrombectomy for stroke complicating cerebral venous thrombosis: The cleveland clinic experience. Stroke. 2006;37:662.
222 Russo MJ, Chaer RA, Lin SC, et al. Percutaneous endovascular treatment of acute sequential systemic emboli. J Vasc Surg. 2006;43:388-92. [pmid: 16476620].
223 Safian RD, Bacharach JM, Ansel GM, et al. Carotid stenting with a new system for distal embolic protection and stenting in high-risk patients: The carotid revascularization with ev3 arterial technology evolution (CREATE) feasibility trial. Catheter Cardio Inte. 2004;63:1-6.
224 Sakai K, Nitta J, Horiuchi T, et al. Emergency revascularization for acute main-trunk occlusion in the anterior circulation. Neurosurg Rev. 2008;31:69-76. [pmid: 17957395].
225 Santoro A, Bristot R, Paolini S, et al. Radiation injury involving the internal carotid artery: Report of two cases. J Neurosurg Sci. 2000;44:159-64. [pmid: 11126453].
226 Santoro A, Paolini S, Piattella MC, et al. Spontaneous thrombosis of a giant carotid-ophthalmic aneurysm and of the ipsilateral internal carotid. case report. Nuova Rivista di Neurologia. 1997;7:147-50.
227 Sartipy U, Malmstedt J, Holm P, et al. Aorto-carotid bypass for cerebral malperfusion after aortic dissection surgery: A case report. Heart Surg Forum. 2006;9:342-3.
228 Sauvageau E, Samuelson RM, Levy EI, et al. Middle cerebral artery stenting for acute ischemic stroke after unsuccessful merci retrieval. Neurosurgery. 2007;60:701-6. [pmid: 17325617].
229 Schlangen C, Kosinski CM, Mull M, et al. Management of an occluding macro-embolus at the carotid bifurcation. J Neurol. 2008;255:446-7. [pmid: 18365300].
230 Schneiderman J, Feinberg MS, Schwammenthal E, et al. Protruding aortic arch thrombus: Treatment with minimally invasive surgical approach. Jvasc Surg. 2004;40:1083-8.
231 Schonewille WJ, Wijman CA, Michel P, et al. Treatment and outcomes of acute basilar artery occlusion in the basilar artery international cooperation study (BASICS): A prospective registry study. Lancet Neurol. 2009;8:724-30. [pmid: 19577962].
232 Schulte-Altedorneburg G. The effectivity of intraarterial thrombolysis in acute occlusion of the proximal middle cerebral artery. Radiologe. 2008;48:228.
233 Schulte-Altedorneburg G, Bruckmann H, Hamann GF, et al. Ischemic and hemorrhagic complications after intra-arterial fibrinolysis in vertebrobasilar occlusion. AJNR Am J Neuroradiol. 2007;28:378-81. [pmid: 17297016].
234 Sekhar LN, Iwai Y, Wright DC, et al. Vein graft replacement of the middle cerebral artery after unsuccessful embolectomy: Case report. Neurosurgery. 1993;33:723-7. [pmid: 8232814].
235 Selaru D, Radocea R, Stanca H. Inferior temporal branch arterial occlusion--acute form. Oftalmologia. 2008;52:64-71. [pmid: 18714493].
236 Setacci C, de Donato G, Chisci E, et al. Rationale and design of Emergent/Urgent carotid artery stenting (EUCAS) registry. J Cardiovasc Surg. 2008;49:737-42. [pmid: 19043387].
237 Setacci C, de Donato G, Setacci F, et al. In-stent restenosis after carotid angioplasty and stenting: A challenge for the vascular surgeon. Eur J Vasc Endovasc. 2005;29:601-7.
238 Shah QA, Memon MZ, Tummala RP, et al. Combined surgical and endovascular approach to treat symptomatic in-stent occlusion of the left common carotid artery origin: Technical note. J Neurosurg. 2009;110:935-8. [pmid: 19072307].
239 Sheehan MK, Greisler HP, Littooy FN, et al. The effect of intraoperative duplex on the management of postoperative stroke. Surgery. 2002;132:761-6. [pmid: 12407363].
240 Shhadeh A, Sarkar A, Hassan A, et al. Predictors of recanalization and outcome of multimodal endovascular therapy for acute ischemic stroke: Early treatment versus modality. Neurology. 2009;11(Suppl3):A290.
241 Shi Y, Meng X, Cai T, et al. Intracranial arterial thrombolysis and mechanical fragmentation in patients with acute infarction. J Intervent Radiol. 2008;17:309-12.
242 Shi Z, Liebeskind DS, Saver JL, et al. Subarachnoid hemorrhage in acute stroke is more common with mechanical revascularization than intra-arterial thrombolysis. Stroke. 2009;40:E272.
243 Silver B, Gulka I, Nicolle M, et al. Idiopathic free-floating thrombus of the common carotid artery. Can J Neurol Sci. 2002;29:97-9. [pmid: 11858545].
244 Silverman IE, Beland DK, Bohannon RW, et al. Expanding the range of therapies for acute ischemic stroke: The early experience of the regional stroke center at hartford hospital. Conn Med. 2004;68:419-29. [pmid: 15384240].
245 Skelly CL, Gallagher K, Fairman RM, Carpenter, et al. Risk factors for restenosis after carotid artery angioplasty and stenting. J Vasc Surg. 2006;4:1010-5. [pmid: 17098535].
246 Smith WS. Safety of mechanical thrombectomy and intravenous tissue plasminogen activator in acute ischemic stroke. results of the multi mechanical embolus removal in cerebral ischemia (MERCI) trial, part I. Am J Neuroradiol. 2006;27:1177-82. [pmid: 16775259].
247 Soleau SW, Schmidt R, Stevens S, et al. Extensive experience with dural sinus thrombosis. Neurosurgery. 2003;52:534-44. [pmid: 12590677].
248 Sosa T, Erdelez L, Macina AS, et al. Carotid endarterectomy in asymptomatic patients. Acta Clin Croat, Supplement. 1998;37:69.
249 Spengel FA, Ruthlein VM, Kuffer GV. Percutaneous transluminal catheter thrombectomy. An additional method to local catheter lysis. Vasa -J Vascular Dis. 1988;17:168-l69.
250 Spetzger U, Reul J, Thron A, et al. Microsurgical embolectomy and removal of a migrated coil from the middle cerebral artery. Cerebravasc Dis. 1997;7:226-31.
251 Starkman S. MERCI Investigators. Results of the combined MERCI (R) I-II (mechanical embolus removal in cerebral ischemia) trials. Stroke. 2004;35:240.
252 Stead LG, Gilmore RM, Bellolio MF, et al. Percutaneous clot removal devices in acute ischemic stroke: A systematic review and meta -analysis. Arch Neurol. 2008;65:1024-30. [pmid: 18695052].
253 Sturm JT, Toro C, Snyder BD. Emergency carotid artery thrombectomy for postpartum hemiplegia. Am J Emerg Med. 1987;5:291-3. [pmid: 3593493].
254 Sugg RM, Malkoff MD, Noser EA, et al. Endovascular recanalization of internal carotid artery occlusion in acute ischemic stroke. AJNR Am J Neuroradiol. 2005;26:2591-4. [pmid: 16286407].
255 Sugg RM, Malkoff MD, Shaltoni HM, et al. Endovascular recanalization of internal carotid occlusion in acute ischemic stroke. Neurology. 2005;64(Suppl1):A111.
256 Suh SH, Lee KY, Hong CK, et al. Temporary stenting and retrieval of the self-expandable, intracranial stent in acute middle cerebral artery occlusion. Neuroradiology. 2009;51:541-4. [pmid: 19424689].
257 Sunder Plassmann L, Hildebrandt U. Arterial embolectomy and venous thrombectomy in the old patient: Risks and results. Aktuelle Gerontol. 1983;13:136-8. [pmid: 6137156].
258 Syrek JR, Calligaro KD, Dougherty MJ, et al. Five-step protocol for carotid endarterectomy in the managed health care era. Surgery. 1999;125:96-101. [pmid: 9889804].
259 Takach TJ, Reul GJ Jr, Round ME, et al. Preocclusive carotid artery thrombosis: Pathogenesis and management. Vasc Surg. 1999;33:691-6.
260 Tanne D, Levine SR. Safer thrombolysis for acute ischemic stroke: Is early recanalization the key?. Neurology. 2008;71:1300-1. [pmid: 18936422].
261 Taoka T, Yuh WT, Chaloupka JC, et al. Assessing reperfusion by angiogram and immediate post-contrast CT in acute stroke treated with endovascular recanalization. Radiology. 2000;217:776.
262 Tenser MS, Liebeskind DS, Starkman S, et al. In: Deterioration following improvement in acute stroke patients after endovascular recanalization therapy. Stroke. 2009;40:E249.
263 Terada T, Yamaga H, Tsumoto T, et al. Use of an embolic protection system during endovascular recanalization of a totally occluded cervical internal carotid artery at the chronic stage. J Neurosurg. 2005;102:558-64. [pmid: 15796397].
264 Theiss W, Hermanek P, Mathias K, et al. Pro-CAS: A prospective registry of carotid angioplasty and stenting. Stroke. 2004;35:2134-9. [pmid: 15232119].
265 Topaz O. Focus on the infarct -related artery: A thrombus runs through it. Catheter Cardio Inte. 2002;57:340-1.
266 Touho H, Morisako T, Hashimoto Y, et al. Embolectomy for acute embolic occlusion of the internal carotid artery bifurcation. Surg Neurol. 1999;51:313-20. [pmid: 10086497].
267 Toyoda K, Uda K, Shirakawa A, et al. Combined and staged endovascular recanalization of cervical and intracranial arteries in hyperacute ischemic stroke. Intern Med. 2007;46:1935-6. [pmid: 18057769].
268 Turnbull RG, Tsang VT, Teal PA, et al. Successful innominate thromboembolectomy of a paradoxic embolus. J Vasc Surg. 1998;28:742-5. [pmid: 9786276].
269 Vallee JN, Crozier S, Guillevin R, et al. Acute basilar artery occlusion treated by thromboaspiration in a cocaine and ecstasy abuser. Neurology. 2003;61:839-41. [pmid: 14504335].
270 Van Damme H, Sakalihasan N, Limet R. Fibromuscular dysplasia of the internal carotid artery. personal experience with 13 cases and literature review. Acta Chir Belg. 1999:163-8. [pmid: 10499386].
271 Van Der Hoek C, Van Groenendael JHLM, Gratama S. Disseminated cholesterol-emboli, renal failure and eosinophilia. Ned Tijdschr Geneeskd. 1979;123:1017-20. [pmid: 471088].
272 Vázquez-Barquero A, Quintana F, Austin O, et al. Emergency embolectomy of middle cerebral artery occlusion due to microcoil migration: Case report. Surg Neurol. 1994;42:135-7. [pmid: 8091290].
273 Vora NA, Gupta R, Thomas AJ, et al. Factors predicting hemorrhagic complications after multimodal reperfusion therapy for acute ischemic stroke. Am J Neuroradiol. 2007;28:1391-4. [pmid: 17698549].
274 Weis-Muller BT, Huber R, Spivak-Dats A, et al. Indication for emergent revascularisation of acute carotid occlusion. Chirurg. 2007;78:1041-8. [pmid: 17805499].
275 Wen H, Du J, Li J. Comparison of the therapeutic effect between interventional treatment and anticoagulation therapy alone in patients with intracranial venous sinus thrombosis. Chinese Journal of Cerebrovascular Diseases. 2009;6:24-8.
276 Willis SL, Welch TS, Scally JP, et al. Impending paradoxical embolism presenting as a pulmonary embolism, transient ischemic attack, and myocardial infarction. Chest. 2007;132:1358-60. [pmid: 17934122].
277 Xu G, Cheng S, Liu X. Focus on endovascular solutions for cerebrovascular diseases: Report of the fourth international stroke summit, nanjing, china, july 25–27, 2008. Cerebrovasc Dis. 2008;26:667-8. [pmid: 19023199].
278 Xu GF, Dae CS, Choong GC, et al. Aspiration thrombectomy of acute complete carotid bulb occlusion. J Vasc Interv Radiol. 2005;16:539-42. [pmid: 15802455].
279 Xv J, Qiao X, Chen J, et al. Exploration of the cause and treatment of recurrent traumatic carotid cavernous fistula after endovascular embolization. Chin J Contemp Neurol Neurosurg. 2009;9:50-4.
280 Yano T, Sakai N, Yamagami H, et al. Revascularization procedure mainly by suction thrombectomy for acute cervical carotid occlusion. Interv Neuroradiol. 2007;13:174-8. [pmid: 20566098].
281 Yassa AS, Bellolio MF, Dajani N, et al. In: TIMI flow obtained after mechanical embolectomy for acute ishemic stroke and its impact on functional outcome. Ann Emerg Med. 2007;50(Suppl1):104.
282 Yousaf M, Atherton ME, Culp WC. Incomplete modeling of the thromboembolectomy technique. Stroke. 2008;39:e127. [pmid: 18583558].
283 Yu W, Kostanian V, Fisher M. Endovascular recanalization of basilar artery occlusion 80 days after symptom onset. Stroke. 2007;38:1387-9. [pmid: 17322092].
284 Zarins CK, Shaver DM, Arko FR, et al. Introduction of endovascular aneurysm repair into community practice: Initial results with a new food and drug administration - approved device. J Vasc Surg. 2002;36:226-33. [pmid: 12170201].
285 Zhou W, Lin PH, Bush RL, et al. Carotid artery aneurysm: Evolution of management over two decades. J Vasc Surg. 2006;43:493-6. [pmid: 16520161].
286 Zlotnik EI. Thrombectomy of the middle cerebral artery. case report. J Neurosurg. 1975;42:723-5. [pmid: 1141968].
287 Zlotnik EI. Thrombectomy in occlusion of the middle cerebral artery (russian). Zhurnal Voprosy Nejrokhirurgii Imeni NNBurdenko. 1973;37:25-8.