# MEDLINE and CENTRAL Search Strategies

## MEDLINE (OVID)

1. thrombectomy
2. embolectomy
3. endovascular recanalization
4. endovascular embolectomy
5. mechanical thrombolysis
6. mechanical embolus removal
7. mechanical thrombus removal
8. endovascular intervention
9. endovascular device
10. mechanical device
11. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10
12. stroke
13. acute stroke
14. cerebrovascular accident
15. cva
16. vascular accident
17. artery occlusion
18. cerebral ischemia
19. acute ischemic stroke
20. 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19
21. 11 and 20

## CENTRAL (OVID)

1. thrombectomy
2. embolectomy
3. endovascular recanalization
4. endovascular embolectomy
5. mechanical thrombolysis
6. mechanical embolus removal
7. mechanical thrombus removal
8. endovascular intervention
9. endovascular device
10. mechanical device
11. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10
12. stroke
13. acute stroke
14. cerebrovascular accident
15. cva
16. vascular accident
17. artery occlusion
18. cerebral ischemia
19. acute ischemic stroke
20. 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19
21. 11 and 20