# Results

## Summary of Engagement with Key Informants

We engaged nine Key Informants: two caregivers and seven clinicians/researchers who are experts in palliative care and assessment tools in areas including oncology, geriatrics, pediatrics, critical care, hospice, tool development, palliative care quality indicators, and evaluation of palliative care interventions.

### Caregivers

Both caregivers reported completing numerous written questionnaires with “tons of questions,” which overwhelmed them and became so granular that the caregivers felt they could not provide an accurate depiction of their experience and the issues that mattered most to them. Caregivers also felt that the way the assessments were administered “always felt rushed” in that they did not have time to reflect on the questions and often just indicated “their initial thoughts” or just “bubbled in an answer”. They felt that the information captured in the tools was meaningful to clinicians, but they were not convinced the tools impacted patients or families.

To enhance the efficacy of detailed assessment tools, the advocates suggested that any encounter or survey should start with a question to identify the patient or family member's unique “biggest concern,” and surveys or questionnaires should ultimately empower the patient or family member to “say what is on his or her mind.” For example, one caregiver supported her mother while she took care of her stepfather. The mother's biggest concern was learning how she could keep her husband at home until the end of his life; this concern was not otherwise a priority for the physician.

### Providers

Discussions with providers were focused on their experiences with the assessment tools. Many felt that these tools were being used appropriately in research but they were not used often enough in clinical care delivery or as quality indicators. Providers agreed that the eight domains and the “cross domains” category (multidimensional area) added by this team were valid, but they noted that more specificity is required in each domain and that the domains still do not address some crucial aspects of palliative care (e.g., overall scale of experience, advance care planning, and informed decision making). They specifically noted that there are few tools that assess the spiritual domain. They noted significant confounding between the care delivered and the experience of that care, as well as difficulty in assessing communication (including disagreement about whether communication is a process or an outcome).

The providers noted several issues related to the successful use of assessment tools. First, owing to their illnesses, patients are often unable to complete complex or lengthy assessment tools. Second, assessment tools as quality indicators are an inherent contradiction, which may result in poor or easily misconstrued measurements: “successful” palliative interventions do not typically lead to an improvement in assessment tool-based scores but, rather, to a slowing in the decline of impairments. Third, many tools include “ceiling effects” with consequent limitations in responsiveness or ability to detect change, particularly in patient experience metrics. Fourth, if used as quality indicators, some assessment tools could unintentionally incentivize actions that are detrimental to patient care, such as treating pain aggressively to bring down pain scores included in the tools, rather than balancing pain management with risks and harms of treatments, such as sedation, that are not included in the tools. Finally, the providers also raised concerns that long, detailed assessments are often not completed and, thus, cannot capture a global assessment of the patient's actual clinical experience.

## Systematic Review and Supplemental Searches

For the systematic review search, we identified 354 unique citations, of which 40 systematic reviews were eligible for inclusion. From these, we selected ten recent high-quality systematic reviews: seven addressing domains of palliative care and three addressing applications of palliative care assessment tools. (Note: the systematic review for interventions, published after our search date, was brought to our attention by one of our advisors.)

For three (physical, care at the end of life, and multidimensional) of the nine domains we identified key subdomains (Figure 1). For the physical domain, these key subdomains are pain, dyspnea, and fatigue. For the care at the end of life domain, the key subdomain was bereavement. For the multidimensional domain, we determined the key subdomains to be quality of life and patient experience. Only one domain (social) and one subdomain (bereavement) had systematic reviews with search strategies that were less than three years old such that we did not complete a supplemental search. Two domains (psychological and psychiatric; spiritual, religious, and existential) and three subdomains (dyspnea; quality of life; patient experience) had systematic reviews with search strategies greater than three years old and thus required supplemental searches. Three domains (structure and process; cultural; ethical and legal) and two subdomains (pain; fatigue) lacked any recent systematic review (Table 1). There was only one domain (cultural) for which we identified no tools through either systematic reviews or our supplemental search, including a targeted search of PubMed (Appendix H, Figure H-2).

Table 1 Summary of the search for palliative care assessment tools

Domain or Application | Identified in Systematic Review, N | Identified in Supplemental Search, N | Source of Information | Search Dates of the Systematic Reviews
Domains
1. Structure and Process of Care | 0 | 2 | 1 Website 1 Supplemental comprehensive review^11^ | NA
2. Physical--Dyspnea | 26 | 0 | 1 Systematic review^18^ | Up to September 2005
2. Physical—Pain | 0 | 25 | 2 Websites | NA
2. Physical—Fatigue | 0 | 7 | 2 Websites | NA
3. Psychological and Psychiatric | 8 | 18 | 1 Systematic review^19^ 4 Websites 1 Supplemental comprehensive review^11^ | 1960 to unspecified end date
4. Social Aspects of Care | 8 | Not done | 1 Systematic review^20^ | Up to September 2014
5. Spiritual, Religious, and Existential | 2 | 0 | 1 Systematic review^21^ (Supplemental search completed but no new tools identified) | Up to June 2010
6. Cultural | 0 | 0 | none | NA
7. Care at the End of Life—Bereavement | 17 | Not done | 1 Systematic review, ^22^ | Up to August 2014
8. Ethical and Legal | 0 | 2 | 1 Website | NA
9. Multidimensional Tools—Quality of Life | 28 | 0 | 1 Systematic review^23^ | January 1990 to April 2008
9. Multidimensional Tools—Patient Experience | 8 | 1 | 1 Systematic review^24^ 1 Website | January 1990 to June 2012
Total Number of Tools | 97 | 55
Applications
Clinical Care | 6 | NA | 1 Systematic review^25^ | 1985 to August 2011
Quality Indicators | 1 | NA | 1 Systematic review^26^ | Up to October 2011
Interventions | 23 | NA | 1 Systematic review^27^ | Up to December 2015

NA=not applicable

We identified a total of 152 tools; 97 tools were identified from systematic reviews, and supplemental searches identified an additional 55 tools (Table 1; Appendix H, Figure H-1). A list of all identified tools organized by domain or subdomain is available in Appendix I.

## State of the Research on Assessment Tools by Domain and Key Subdomains (Guiding Questions 1 and 2)

### Domain 1 Structure and Process

We did not identify a systematic review for this domain. In a supplemental search, we identified two tools (Appendix J, Evidence Table 1).

### Domain 2 Physical

Physical symptoms include multiple subdomains such as pain, shortness of breath, nausea, fatigue, anorexia, insomnia, restlessness, confusion, and constipation. Based on subdomains addressed in previous reviews, we summarized assessment tools for the three key subdomains of: dyspnea, pain, and fatigue.^8, 11-13, 17^

#### Physical - Subdomain: Dyspnea

We selected one systematic review - Dorman 2007^18^ – which identified 26 tools that met our inclusion criteria. Tools addressed severity, descriptions, and functional impact or limitations related to dyspnea. Settings included inpatient and outpatient care and home settings and a wide variety of conditions, including cancer, chronic obstructive pulmonary disease, heart failure, and other lung conditions. The review reported internal consistency reliability for 14 tools, convergent validity for 23 tools, and responsiveness was reported for only eight tools. The review reported usability (i.e., time to complete) for 15 tools (Table 2; Appendix J, Evidence Tables 2a-2e).

Table 2 Summary table of tools addressing physical domain (dyspnea subdomain) identified from Dorman et al., 2007^18^

Tool | Population | Internal Consistency Reliability Measured | Convergent Validity Measured | Discriminant or Criterion Validity Measured | Responsiveness Measured | Time to Complete Measured | Number of Items
Visual Analogue Scale ^ 28 ^ | Asthma, COPD, ventilated | NA | Y | Y | N | Y | 1
Numeric Rating Scale or Dyspnea Numeric Scale ^29, 30^ | Cancer, COPD | NA | Y | Y | N | Y | 1
Modified Borg Scale ^ 31 ^ | COPD, restrictive lung disease, asthma | NA | Y | Y | N | Y | 1
Global Shortness of Breath Question ^ 32 ^ | COPD | NA | Y | N | Y | N | 1
Faces Scale ^ 33 ^ | Ventilated | NA | Y | N | N | N | 1
Dyspnea Descriptor Questionnaire (heart failure) ^ 34 ^ | Heart failure | Y | N | N | N | N | 13
Dyspnea Descriptor Questionnaire (COPD) ^ 35 ^ | COPD | Y | N | N | N | N | 16
Dyspnea Assessment Questionnaire ^ 36 ^ | Cancer | N | Y | N | N | N | 43
Amyotrophic Lateral Sclerosis Functional Rating Scale – revised ^ 37 ^ | MND (Motor Neuron Disease) | Y | Y | N | N | N | 3
American Thoracic Society Division of Lung Diseases 1978 Dyspnea Scale ^ 38 ^ | COPD, asthma | Y | Y | N | N | Y | 5
Breathlessness, Cough and Sputum Scale ^ 39 ^ | COPD | NA | Y | Y | Y | N | 1
Chronic Heart Failure Questionnaire – dyspnea subscale ^ 40 ^ | Heart failure | Y | Y | Y | Y | Y | 5
Cardiovascular Limitations and Symptoms Profile ^ 41 ^ | Ischemic heart disease | N | Y | N | N | Y | 6
Chronic Lung Disease Severity Index ^ 42 ^ | Chronic lung disease | Y | Y | N | N | N | 2
Chronic Respiratory Questionnaire – dyspnea subscale ^ 43 ^ | COPD, interstitial lung disease, cystic fibrosis, alpha antitrypsin deficiency, MND | Y | Y | Y | Y | Y | 5
Chronic Respiratory Questionnaire – Standardized dyspnea questions ^ 44 ^ | ND | N | N | N | N | N | 5
European Organization for Research and Treatment of Cancer Quality of Life Questionnaire; Lung Cancer supplement, breathlessness subscale ^ 45 ^ | Lung cancer | Y | Y | Y | N | N | 3
London Chest Activity of Daily Living Scale ^ 46 ^ | COPD | Y | Y | Y | N | N | 15
Motor Neuron Disease Dyspnea Rating Scale ^ 47 ^ | MND | Y | Y | N | N | Y | 5
Medical Research Council Dyspnea Scale ^ 48 ^ | COPD, interstitial lung disease, asthma, other | N | Y | Y | N | Y | 1
Oxygen Cost Diagram ^ 49 ^ | Respiratory disease, COPD, heart failure | NA | Y | N | Y | Y | 1
Pulmonary Functional Status and Dyspnea Questionnaire – modified ^ 50 ^ | COPD | Y | Y | Y | N | Y | 5
Rand Instrument ^ 51 ^ | Heart failure, respiratory disease | N | Y | N | Y | Y | 9
St George's Respiratory Questionnaire ^ 52 ^ | COPD, asthma, bronchiectasis | Y | Y | Y | Y | Y | 16
University of Cincinnati Dyspnea Questionnaire ^ 53 ^ | Asthma, sarcoid, COPD, fibrosis | Y | Y | N | N | Y | 30
University of California San Diego Shortness of Breath Questionnaire ^ 54 ^ | COPD, asthma, cystic fibrosis, lung transplant | Y | Y | N | Y | Y | 24

COPD=chronic obstructive pulmonary disease; MND=motor neuron disease; N=not measured for tool; NA=not applicable; ND=not described in review; Y=measured for tool

#### Physical – Subdomain: Pain

We did not identify any high-quality, recent systematic review for the subdomain of pain. We identified 25 tools in our supplemental search (Appendix J, Evidence Table 1).

#### Physical – Subdomain: Fatigue

We did not identify any high-quality, recent systematic review for the subdomain of fatigue. Our supplemental search identified seven tools (Appendix J, Evidence Table 1).

### Domain 3 Psychological and Psychiatric

The Ziegler 2011 systematic review^19^ included eight tools that met our inclusion criteria. Tools were tested in the following settings: inpatient and outpatient care and a palliative care unit, and included cancer patients with advanced disease and cancer patients at the time of first cancer recurrence. The tools addressed depression, anxiety, distress, and psychological response to cancer. No tools had data on responsiveness or usability (time to complete); one tool had data on internal consistency reliability and seven tools had data on convergent validity in the palliative care population (Table 3; Appendix J, Evidence Tables 3a-3e).

Table 3 Summary table of tools addressing psychological and psychiatric domain identified from Ziegler et al., 2011^19^

Tool | Population | Internal Consistency Reliability Measured | Convergent Validity Measured | Criterion or Discriminant Validity Measured | Responsiveness Measured | Time to Complete Measured | Number of Items
Hospital Anxiety and Depression Scale ^ 57 ^ | Patients receiving palliative care with a prognosis of six months or less | N | Y | ND | N | Y | 14
Two Single Items: “Are you depressed?” and “Have you lost interest?” ^ 58 ^ | Palliative care population | N | Y | ND | N | Y | 2
Distress Thermometer (via touch screen) ^ 59 ^ | Patients with advanced disease | N | Y | ND | N | Y | 1
Brief Symptom Inventory-18 item (via touch screen) ^ 59 ^ | Patients with advanced disease | N | Y | ND | N | Y | 18
General Health Questionnaire-12 item ^ 59 ^ | Patients with advanced disease | N | Y | ND | N | Y | 12
Brief Edinburgh Depression Scale ^ 60 ^ | Patients receiving palliative care with a prognosis of six months or less | Y | Y | ND | N | Y | 6
Beck Depression Inventory-Short Form ^ 57 ^ | Patients with metastatic breast cancer | N | Y | ND | N | Y | 13
Mental Adjustment to Cancer ^ 61 ^ | Patients at first recurrence of breast cancer | N | N | ND | N | N | 40

Y=measured for tool, N=not measured for tool, ND=not described in review

Because the search from the systematic review for this domain was greater than three years old and addressed only cancer, we completed a supplemental search that yielded 18 additional tools (Appendix J, Evidence Table 1).

### Domain 4 Social Aspects of Care

The Michels 2016 systematic review^20^ included eight tools that met our inclusion criteria: caregiver-reported assessment tools that addressed outcomes of informal caregivers (i.e., caregiver burden, strain and quality of life). The review reported information on internal consistency reliability for all tools, convergent validity for seven tools, and responsiveness for three tools. The assessment tools ranged from 13 to 35 items, with only one tool with information on usability (time to complete) (Table 4; Appendix J, Evidence Tables 4a-4e).

Table 4 Summary table of tools addressing social domain identified from Michels et al., 2016^20^

Tool | Population | Internal Consistency Reliability Measured | Convergent Validity Measured | Criterion or Discriminant Validity Measured | Responsiveness Measured | Time to Complete Measured | Number of Items
Caregiver's Burden Scale in End-of-life Care ^ 62 ^ | Family caregivers of patients with terminal cancer | Y | Y | Y | Y | N | 16
Caregiver Impact Scale ^ 63 ^ | Caregivers of patients with advanced cancer | Y | N | N | N | N | 14
Caregiver Quality of Life Index – Cancer ^ 64 ^ | Caregivers of patients with cancer | Y | Y | Y | Y | Y | 35
Caregiver Reaction Assessment ^ 65 ^ | Caregivers of patients receiving palliative care | Y | Y | N | N | N | 24
Caregiver Strain Index ^ 66 ^ | Caregivers for patients with symptomatic advanced cancer | Y | Y | N | N | N | 13
Family Appraisal of Caregiving Questionnaire for Palliative Care ^ 67 ^ | Caregivers of patients receiving palliative care | Y | Y | N | N | N | 26
Quality of Life in Life-Threatening Illness-Family Carer Version ^ 68 ^ | Caregivers of patients receiving palliative care for cancer | Y | Y | N | Y | N | 16
Zarit Burden Inventory ^ 69 ^ | Advanced conditions | Y | Y | N | N | N | 22

Y=measured for tool, N=not measured for tool, ND=not described in review

As the systematic review was published in 2016, we did not conduct a supplemental search.

### Domain 5 Spiritual, Religious, and Existential

The Selman 2011 systematic review^21^ identified two tools that met our inclusion criteria. Of note, the review collected and described assessment tools for spirituality as defined by “religious faith as well as existential/humanist positions” and “applicable to all human beings” and no specific target population was pre-identified for the search. The two tools, The Beck Hopelessness Scale and the Ironson-Woods Spirituality/Religiousness Index, specifically address spirituality and are evaluated in an ethnically diverse U.S. palliative care population (i.e., the Beck Hopelessness Scale was validated in populations including AIDS patients and hospice inpatients with cancer; the Ironson-Woods Spirituality/Religiousness Index was validated in an HIV/AIDS population).^55, 56^ Both tools had information on internal consistency reliability, convergent validity, criterion or discriminant validity, and responsiveness but no information on usability (time to complete) (Table 5; Appendix J, Evidence Tables 5a-5e).

Table 5 Summary table of tools addressing spiritual, religious, and existential domain identified from Selman et al., 2011^21^

Tool | Population | Internal Consistency Reliability Measured | Convergent Validity Measured | Criterion or Discriminant Validity Measured | Responsiveness Measured | Time to Complete Measured | Number of Items
Beck Hopelessness Scale ^55, 70, 71^ | Ethnically diverse U.S. population; validated in palliative care population | Y | Y | Y | Y | N | 120
Ironson-Woods Spirituality/Religiousness Index ^ 56 ^ | Ethnically diverse U.S. population | Y | Y | Y | Y | N | 22

Y=measured for tool, N=not measured for tool, ND=not described in review

Because the search from the systematic review was more than three years old, we completed a supplemental search, but did not identify any additional tools.

### Domain 6 Cultural

The cultural domain refers to whether care is sensitive to a patient's culture, race, or ethnicity. We identified no existing systematic review or eligible tools that focused on the cultural domain. In addition to completing the supplemental search, we also evaluated whether any of the tools addressing the multidimensional domain had items that addressed the cultural domain, and none did.

### Domain 7 Care at the End of Life

The care at the end of life domain includes multiple subdomains such as bereavement, quality of death, symptom scores immediately prior to death, or caregiver assessments of the quality of death. Based on subdomains addressed in previous reviews, we selected the key subdomain of bereavement.^8, 11-13, 17^

### Subdomain: Bereavement

The Sealey 2015 systematic review^22^ identified 17 tools that met our inclusion criteria. The review did not define settings where the tools are tested, and tools are only for bereaved adults and caregivers (not patients). Some tools addressed specific patient populations (e.g., patients with dementia, cancer, trauma, or in hospice) or specific caregiver populations (e.g., spouses or those with prolonged grief disorder). The tools are designed for pre-death bereavement risk, after-death bereavement assessment, or for the assessment of complicated or prolonged bereavement. All tools had information on internal consistency reliability. Three tools had data on convergent validity. None of the tools had data on responsiveness, and only two had data on usability (time to complete). The number of items ranged widely from five to 91 items (Table 6; Appendix J, Evidence Tables 6a-6e).

Table 6 Summary table of tools addressing care at the end of life domain (bereavement subdomain) identified from Sealey et al., 2015^22^

Tool | Population | Internal Consistency Reliability Measured | Convergent Validity Measured | Criterion or Discriminant Validity Measured | Responsiveness Measured | Time to Complete Measured | Number of Items
Bereavement Experience Questionnaire–24 ^ 72 ^ | Bereaved adults | Y | N | ND | N | N | 24
Brief Grief Questionnaire ^73-75^ | Recipients of crisis counselling following 911 terrorist attacks; bereaved community-dwelling adults | Y | N | ND | N | N | 5
Core Bereavement Items ^ 76 ^ | Bereaved adults | Y | Y | ND | N | N | 17
Grief Evaluation Measure ^ 77 ^ | Bereaved adults | Y | N | ND | N | Y | 91
Grief Experience Questionnaire ^ 78 ^ | Bereaved spouses | Y | N | ND | N | Y | 55
Hogan Grief Reaction Checklist ^ 79 ^ | Parentally bereaved people | Y | N | ND | N | N | 61
Inventory of Complicated Grief ^ 80 ^ | Bereaved spouses | Y | N | ND | N | N | 19
Inventory of Complicated Grief–Revised ^81-83^ | Bereaved spouses | Y | N | ND | N | N | 15
Inventory of Traumatic Grief ^ 84 ^ | Elderly widowed residents; bereaved adults | Y | N | ND | N | N | 34
Marwit–Meuser Caregiver Grief Inventory ^85-87^ | Caregivers of people with dementia, acquired brain injury, cancer | Y | Y | ND | N | N | 50
Marwit–Meuser Caregiver Grief Inventory–Short Form ^ 88 ^ | Adult caregivers of people with dementia | Y | Y | ND | N | N | 18
Prolonged Grief–12 ^89, 90^ | Caregivers of people with dementia, hospice patients | Y | N | ND | N | N | 12
Prolonged Grief–13 ^91, 92^ | Adults; bereaved caregivers with prolonged grief disorder | Y | N | ND | N | N | 13
Revised Grief Experience Inventory^93^ | Hospice caregivers following the death of a loved one | Y | N | ND | N | N | 22
Texas Revised Inventory of Grief^94-97^ | Bereaved psychiatric outpatients; bereaved adults | Y | N | ND | N | N | 21
Two-Track Bereavement Questionnaire^98^ | Bereaved adults | Y | N | ND | N | N | 70
Two-Track Bereavement Questionnaire–CG30^*,99^ | Adults bereaved by traumatic deaths | Y | N | ND | N | N | 30

Y=measured for tool, N=not measured for tool, ND=not described in review

* Reference given in the systematic review for the Two-Track Bereavement Questionnaire-CG30 is a conference abstract. We were unable to retrieve the abstract to verify, after exhausting all resources.

We did not conduct a supplemental search because the systematic review search strategy was conducted through 2014.

### Domain 8 Ethical and Legal

We did not identify any systematic reviews focusing on tools addressing the ethical and legal domain. We completed a supplemental search which identified two eligible tools, the Relatives' Patient Management questionnaire and the Willingness to Accept Life-sustaining Treatment instrument (Appendix J, Evidence Table 1).

### Domain 9 Multidimensional

Multidimensional tools can include subdomains such as quality of life, patient experience, or satisfaction with care. Based on subdomains addressed in previous reviews,^8, 11-13, 17^ we selected the two key subdomains quality of life (which may include areas such as physical health and functional status, mental health, social and role function, and physical and psychological symptoms) and patient experience.

#### Subdomain - Quality of Life

The Albers 2010 systematic review^23^ identified 28 tools that met our inclusion criteria. The tools were developed for and evaluated in hospice, home care, outpatient and inpatient settings (including palliative care units), and long term care. Populations included palliative care patients, seriously ill patients, cancer patients, and patients near the end of life. Many tools contained items that addressed most domains, including structure and process (four tools), physical (21 tools), psychological and psychiatric (20 tools), spiritual, religious and existential (11 tools), social (11 tools), ethical and legal (six tools) and care at the end of life (two tools) (Table 7). No tools contained items that addressed the cultural domain. All tools had data on internal consistency reliability, while 27 had data about convergent validity, seven had data on responsiveness, and 14 had data on usability (time to complete) (Appendix J, Evidence Tables 7a-7e).

Table 7 Summary table of tools addressing multidimensional domain (quality of life subdomain) identified from Albers et al., 2010^23^

Tool | Domains Included | Population | Internal Consistency Reliability Measured | Convergent Validity Measured | Discriminant or Criterion Validity Measured | Responsiveness Measured | Time to Complete Measured | Number of Items
Brief Hospice Inventory ^ 100 ^ | Physical, Psychological and Psychiatric | Patients in hospice | Y | N | ND | N | Y | 17
Cambridge Palliative Audit Schedule ^ 101 ^ | Physical, Psychological and Psychiatric | Patients receiving palliative care | Y | Y | ND | Y | N | 2×10
Demoralization Scale ^ 102 ^ | Psychological and Psychiatric | Patients with cancer | Y | Y | ND | N | N | 24
Edmonton Functional Assessment Tool ^103, 104^ | Physical | Patients with cancer | Y | Y | ND | N | N | 11
Emanuel and Emanuel Medical Directive ^ 105 ^ | Ethical/Legal | Patients who are severely ill | Y | Y | ND | Y | Y | 48
European Organisation for Research and Treatment of Cancer Quality of Life Questionnaire – Oesophageal Cancer Module ^ 106 ^ | Physical | Patients with esophageal cancer | Y | Y | ND | Y | Y | 18
European Organisation for Research and Treatment of Cancer Quality of Life Questionnaire – Gastric Cancer Module ^ 107 ^ | Physical, Psychological and Psychiatric | Patients with adenoma carcinoma of the stomach | Y | Y | ND | Y | Y | 22
Edmonton Symptom Assessment Scale ^ 108 ^ | Physical, Psychological and Psychiatric | Patients receiving palliative care | Y | Y | ND | N | Y | 10
FACIT-Pal Functional Assessment of Chronic Illness Therapy-Palliative Subscale ^ 109 ^ | Physical, Psychological and Psychiatric, Social, Ethical/Legal | Patients with life limiting illness | Y | Y | ND | N | N | 19
Hospice Quality of Life Index ^110, 111^ | Physical, Psychological and Psychiatric, Social, Spiritual | Patients in hospice | Y | Y | ND | N | Y | 28
Life Closure Scale ^ 112 ^ | Psychological and Psychiatric | Patients who are terminally ill | Y | Y | ND | N | N | 20
Life Evaluation Questionnaire ^ 113 ^ | Psychological and Psychiatric, Social | People with incurable cancer | Y | Y | ND | N | N | 44
McMaster Quality of Life Scale ^ 114 ^ | Physical, Psychological and Psychiatric, Social | Patients receiving palliative care | Y | Y | ND | Y | Y | 32
McGill Quality of Life Questionnaire ^115, 116^ | Physical, Psychological and Psychiatric, Social, Spiritual | People with life threatening illness | Y | Y | ND | Y | Y | 16
McGill Quality of Life Questionnaire-Cardiff Short Form ^ 117 ^ | Physical, Psychological and Psychiatric, Spiritual | Patients who are terminally ill | Y | Y | ND | N | Y | 8
McCanse Readiness for Death Instrument ^ 118 ^ | Physical, Psychological and Psychiatric, Social, Spiritual | Patients who are terminally ill | Y | Y | ND | N | N | 28
Memorial Symptom Assessment Scale ^119, 120^ | Physical, Psychological and Psychiatric | Patients with cancer | Y | Y | ND | N | Y | 32
Condensed Memorial Symptom Assessment Scale ^ 121 ^ | Physical, Psychological and Psychiatric | Patients with cancer | Y | Y | ND | N | Y | 14
Memorial Symptom Assessment Scale-Global Distress Index ^ 122 ^ | Physical, Psychological and Psychiatric | Patients with cancer | Y | N | ND | N | N | 11
Missoula-VITAS Quality of Life Index ^123, 124^ | Physical, Social, Spiritual | Patients who are terminally ill | Y | Y | ND | Y | N | 25
Needs Assessment for Advanced Cancer Patients ^ 125 ^ | Structure and Process, Physical, Social, Spiritual | Patients with advanced cancer | Y | N | ND | N | Y | 132
Patient Autonomy Questionnaire ^ 126 ^ | Ethical/Legal | Patients receiving palliative care for cancer | Y | Y | ND | N | N | 4/9
Patient Dignity Inventory ^ 127 ^ | Physical, Social, Spiritual | Patients nearing the end of life | Y | Y | ND | N | Y | 25
Problems and Needs in Palliative Care Questionnaire ^ 128 ^ | Structure and Process, Physical, Psychological and Psychiatric, Social Spiritual, Ethical/Legal | Patients receiving palliative care | Y | Y | ND | N | N | 138
Problems and Needs in Palliative Care Questionnaire-Short Version ^ 129 ^ | Structure and Process, Physical, Psychological and Psychiatric, Social Spiritual, Ethical/Legal | Patients receiving palliative care | Y | Y | ND | N | N | 33
Palliative care Outcome Scale ^ 130 ^ | Physical, Psychological and Psychiatric, Spiritual | Patients with advanced cancer | Y | Y | ND | Y | Y | 10
Quality of Life at the End of Life ^ 131 ^ | Structure and Process, Psychological and Psychiatric, Ethical/Legal, End of Life | Patients who are seriously ill | Y | Y | ND | N | N | 26
Spiritual Needs Inventory ^ 132 ^ | Spiritual | Patients near the end of life | Y | Y | ND | N | N | 17

Y=measured for tool, N=not measured for tool, ND=not described in review

As the search from the systematic review was greater than three years old, we completed a supplemental search but identified no additional tools.

#### Subdomain - Patient Experience

The Lendon 2015 systematic review^24^ identified eight tools that met our inclusion criteria. Six tools only addressed the caregiver's perception of the patient's quality of end-of-life care, and two addressed the patient's or the caregiver's perception. The tools had a range of 25-74 items and contained items that addressed most domains, including structure and process (six tools), physical (seven tools), psychological and psychiatric (seven tools), spiritual, religious and existential (seven tools), social (five tools), and are at the end of life (five tools); we could not determine from the review whether ethical and legal and cultural domains were addressed (Table 8). Six tools had information on internal consistency reliability. Four had information on convergent validity. None had data on responsiveness or usability (time to complete) (Appendix J, Evidence Tables 8a-8e).

Table 8 Summary table of tools addressing multidimensional domain (patient experience subdomain) identified from Lendon et al., 2015^24,*^

Tool | Domains included | Population | Internal Consistency Reliability Measured | Convergent Validity Measured | Discriminant or Criterion Validity Measured | Responsiveness Measured | Time to Complete Measured | Number of Items
After Death Bereaved Family Member Interview ^133-140^ | Structure and Process, Physical, Spiritual, Psychological and Psychiatric, Social, End of Life | Close relatives, Surrogates, Caregivers | Y | Y | Y | N | N | 74
End of Life in Dementia- Satisfaction with Care & Comfort Assessment in Dying ^136, 141, 142^ | Structure and Process, Physical, Spiritual, Psychological and Psychiatric | Patients or health care proxies, Caregivers | Y | N | N | N | N | 41
Family Assessment of Treatment of End-of-Life Survey ^143-147^ | Structure and Process, Physical, Social, Psychological and Psychiatric, Spiritual, End of Life | Family members | Y | N | Y | N | N | 58
Family Evaluation of Hospice Care ^148-155^ | Structure and Process, Physical, Spiritual, Psychological and Psychiatric, Social, End of Life | Family members | N | N | N | N | N | 56
Family Satisfaction in the ICU ^156-158^ | Structure and Process, Physical, Spiritual, Social, End of Life | Family members | Y | Y | N | N | N | 25
Family Satisfaction with Advanced Cancer Care ^159-166^ | Psychological and Psychiatric, Physical, Social | Caregivers, Family members | N | N | N | N | N | 30
Quality of Dying and Death ^158, 167-171^ | Physical, Psychological and Psychiatric, Spiritual, End of Life | Family members | Y | Y | Y | N | N | 31
Quality of End-of-Life Care and Satisfaction with Treatment ^172-174^ | Structure and Process, Spiritual, Psychological and Psychiatric | Patients, Family members | Y | Y | Y | N | N | 47

Y=measured for tool, N=not measured for tool, ND=not described in review

* Note that ethical and legal, and cultural domains could not be determined from the review.

Because the search from the systematic review was more than three years old, we completed a supplemental search which identified one additional tool, the Caregiver Evaluation of Quality of End-of-Life Care (Appendix J, Evidence Table 1).

## Applications of Assessment Tools (Guiding Question 3)

### Clinical Care

The Antunes 2014 systematic review^25^ evaluated the use of patient-reported outcome measures in clinical care in adults in palliative care settings and found 31 studies evaluating implementation issues. Six studies are conducted in the U.S. and reported on the use of specific assessment tools. The six tools used in these studies included multidimensional tools (quality of life tools, three studies), physical (numerical rating or visual analog scales for pain, two studies), and psychological or psychiatric (one study). We identified four of these tools in systematic reviews (The Edmonton Symptom Assessment Scale, Missoula-VITAS Quality of Life Index, Memorial Symptom Assessment Scale, and Functional Assessment of Chronic Illness Therapy-Lung) and two in our supplemental searches (Numeric Rating Scale for Pain, and Visual Analogue Scale for Pain). Settings included hospices, cancer centers, nursing homes, emergency care, and home. Most clinical care was of cancer patients (Appendix J, Evidence Tables 9a-9b).

### Quality Indicators

The De Roo 2013 systematic review^26^ evaluated quality indicators developed specifically for palliative care. This review identified ten U.S. indicator sets. However, only one indicator specified a palliative care assessment tool (most are indicators abstracted from the medical record, rather than reported by or with patients or caregivers). The one palliative care assessment tool, Family Evaluation of Hospice Care,^175^ was a multidimensional tool assessing patient experience, which we identified from the patient experience systematic review (Lendon, 2015) (Appendix J, Evidence Tables 10a-10b).

### Evaluation of Interventions

The Kavalieratos 2016 systematic review^27^ evaluated assessment tools used in randomized controlled trials of palliative care interventions in adults with terminal or life-limiting illness.^27^ In the 43 included studies evaluating palliative care interventions, the authors found 23 palliative care assessment tools that are used to evaluate the interventions related to the physical domain (seven tools), psychological and psychiatric domain (six tools), patient experience (two tools), or quality of life (six tools). The most commonly used physical domain palliative care assessment tool was the Numeric Rating Scale for Pain, but this was used in only four of the studies. The most commonly used palliative care assessment tool for the psychological and psychiatric domain was the Hospital Anxiety and Depression Scale, which was used in only six of 27 studies evaluating this domain. For multidimensional tools, the most commonly used palliative care assessment tool for quality of life was the Edmonton Symptom Assessment Scale, which was used in only five studies. Two studies used two different multidimensional patient experience palliative care assessment tools (Table 9; Appendix J, Evidence Tables 1 and 11).

Table 9 Summary of palliative care assessment tools that are used in 23 studies evaluating palliative care interventions and how often they were used

Domain, N Tools | Tool (Number of studies in which tool was used)
Physical, 7 tools | Numerical Rating Scale for Pain (4)^†^ Chronic Respiratory Disease Questionnaire (1) University of California, San Diego Shortness of Breath Questionnaire (1) Brief Pain Inventory (2)^†^ Pain as Assessed in the Medical Outcomes Study (1)^†^ Visual Analog Scale for Pain (1)^†^ Memorial Pain Assessment Card (1)^†^
Psychological and Psychiatric, 6 tools | Center for Epidemiologic Studies Depression Scale (5)^†^ Cornell Scale for Depression in Dementia (1)^†^ General Health Questionnaire-12 Item (1) Hospital Anxiety and Depression Scale (6) Impact of Event Scale (1)^†^ Patient Health Questionnaire-9 (4)^†^ Profile of Mood States (4)^†^
Multidimensional - Patient Experience, 2 tools | Family Satisfaction with Advanced Cancer Care (16 item version) (1) McCusker Scale (1)^†^
Multidimensional - Quality of Life, 5 tools | European Organization for Research and Treatment of Cancer Quality of Life Questionnaire-30 Item (2) Edmonton Symptom Assessment Scale (5) Functional Assessment of Chronic Illness Therapy-Palliative Sub Scale (3) Memorial Symptom Assessment Scale (2) McGill Quality of Life Scale (1) Quality of Life at the End of Life (3)

† Indicates tool that was found during supplemental search