# References

1 Dying in America: Improving Quality and Honoring Individual Preferences Near the End of Life. Washington DC: 2015 by the National Academy of Sciences; 2015.
2 National Consensus Project for Quality Palliative Care. Clinical Practice Guidelines for Quality Palliative Care, Third Edition. 2015. http://www.nationalconsensusproject.org. Accessed December 1, 2015.
3 Bruera E, Kuehn N, Miller MJ, . The Edmonton Symptom Assessment System (ESAS): a simple method for the assessment of palliative care patients. J Palliat Care. 1991 Summer;7(2):6-9. PMID: 1714502.1714502
4 Chang VT, Hwang SS, Thaler HT, . Memorial symptom assessment scale. Expert Rev Pharmacoecon Outcomes Res. 2004 Apr;4(2):171-8. doi: 10.1586/14737167.4.2.171. PMID: 19807521.19807521
5 Agency for Healthcare Research and Quality. National Quality Measures Clearinghouse. http://www.qualitymeasures.ahrq.gov/tutorial/varieties.aspx. Accessed February 16 2015.
6 Aslakson RA, Bridges JF. Assessing the impact of palliative care in the intensive care unit through the lens of patient-centered outcomes research. Curr Opin Crit Care. 2013 Oct;19(5):504-10. doi: 10.1097/MCC.0b013e328364d50f. PMID: 23995120.23995120
7 Johnson KS. Racial and ethnic disparities in palliative care. J Palliat Med. 2013 Nov;16(11):1329-34. doi: 10.1089/jpm.2013.9468. PMID: 24073685.24073685
8 Teno J. Toolkit of Instruments to Measure End of Life Care (TIME) Center for Gerontology and Health Care Research. Brown Medical School 2001.
9 NIH State-of-the-Science Conference Statement on improving end-of-life care. NIH Consens State Sci Statements. 2004 Dec 6-8;21(3):1-26. PMID: 17308546.17308546
10 Lorenz K, Lynn J, Morton S, . End-of-Life Care and Outcomes. Evidence Report/Technology Assessment No. 110. AHRQ Publication No. 05-E004-2 Agency for Healthcare Research and Quality. Rockville, MD: 2004.
11 Mularski RA, Dy SM, Shugarman LR, . A systematic review of measures of end-of-life care and its outcomes. Health Serv Res. 2007 Oct;42(5):1848-70. doi: 10.1111/j.1475-6773.2007.00721.x. PMID: 17850523.17850523
12 Dy SM, Shugarman LR, Lorenz KA, . A systematic review of satisfaction with care at the end of life. J Am Geriatr Soc. 2008 Jan;56(1):124-9. doi: 10.1111/j.1532-5415.2007.01507.x. PMID: 18031485.18031485
13 Hanson LC, Scheunemann LP, Zimmerman S, . The PEACE project review of clinical instruments for hospice and palliative care. J Palliat Med. 2010 Oct;13(10):1253-60. doi: 10.1089/jpm.2010.0194. PMID: 20874234.20874234
14 Systematic Reviews of Instruments Relevant to Palliative Care. Palliative Care Research Cooperative; 2016. https://pcrc.app.box.com/v/instrument-reviews. Accessed December 7, 2016.
15 Robinson KA, Chou R, Berkman ND, . Twelve recommendations for integrating existing systematic reviews into new reviews: EPC guidance. J Clin Epidemiol. 2016 Feb;70:38-44. doi: 10.1016/j.jclinepi.2015.05.035. PMID: 26261004.26261004
16 Whiting P, Savovic J, Higgins JP, . ROBIS: A new tool to assess risk of bias in systematic reviews was developed. J Clin Epidemiol. 2016 Jan;69:225-34. doi: 10.1016/j.jclinepi.2015.06.005. PMID: 26092286.26092286
17 Patient Reported Outcomes (PROs) in Performance Measurement. National Quality Form; 2013. https://www.qualityforum.org/Publications/2012/12/Patient-Reported_Outcomes_in_Performance_Measurement.aspx. Accessed December 1, 2015.
18 Dorman S, Byrne A, Edwards A. Which measurement scales should we use to measure breathlessness in palliative care? A systematic review. Palliat Med. 2007 Apr;21(3):177-91. doi: 10.1177/0269216307076398. PMID: 17363394.17363394
19 Ziegler L, Hill K, Neilly L, . Identifying psychological distress at key stages of the cancer illness trajectory: a systematic review of validated self-report measures. J Pain Symptom Manage. 2011 Mar;41(3):619-36. doi: 10.1016/j.jpainsymman.2010.06.024. PMID: 21310585.21310585
20 Michels CT, Boulton M, Adams A, . Psychometric properties of carer-reported outcome measures in palliative care: A systematic review. Palliat Med. 2016 Jan;30(1):23-44. doi: 10.1177/0269216315601930. PMID: 26407683.26407683
21 Selman L, Siegert R, Harding R, . A psychometric evaluation of measures of spirituality validated in culturally diverse palliative care populations. J Pain Symptom Manage. 2011 Oct;42(4):604-22. doi: 10.1016/j.jpainsymman.2011.01.015. PMID: 21640549.21640549
22 Sealey M, Breen LJ, O'Connor M, . A scoping review of bereavement risk assessment measures: Implications for palliative care. Palliat Med. 2015 Jul;29(7):577-89. doi: 10.1177/0269216315576262. PMID: 25805738.25805738
23 Albers G, Echteld MA, de Vet HC, . Evaluation of quality-of-life measures for use in palliative care: a systematic review. Palliat Med. 2010 Jan;24(1):17-37. doi: 10.1177/0269216309346593. PMID: 19843620.19843620
24 Lendon JP, Ahluwalia SC, Walling AM, . Measuring Experience With End-of-Life Care: A Systematic Literature Review. J Pain Symptom Manage. 2015 May;49(5):904-15 e1-3. doi: 10.1016/j.jpainsymman.2014.10.018. PMID: 25543110.25543110
25 Antunes B, Harding R, Higginson IJ. Implementing patient-reported outcome measures in palliative care clinical practice: a systematic review of facilitators and barriers. Palliat Med. 2014 Feb;28(2):158-75. doi: 10.1177/0269216313491619. PMID: 23801463.23801463
26 De Roo ML, Leemans K, Claessen SJ, . Quality indicators for palliative care: update of a systematic review. J Pain Symptom Manage. 2013 Oct;46(4):556-72. doi: 10.1016/j.jpainsymman.2012.09.013. PMID: 23809769.23809769
27 Kavalieratos D, Corbelli J, Zhang D, . Association Between Palliative Care and Patient and Caregiver Outcomes: A Systematic Review and Meta-analysis. 2016;316(20):2104-14. doi: 10.1001/jama.2016.16840. PMID: 27893131.27893131
28 Gift AG. Validation of a vertical visual analogue scale as a measure of clinical dyspnea. Rehabil Nurs 1989 Nov-Dec;14(6):323-5. PMID: 2813949.2813949
29 Gift AG, Narsavage G. Validity of the numeric rating scale as a measure of dyspnea. Am J Crit Care. 1998 May;7(3):200-4. PMID: 9579246.9579246
30 Tanaka K, Akechi T, Okuyama T, . Prevalence and screening of dyspnea interfering with daily life activities in ambulatory patients with advanced lung cancer. J Pain Symptom Manage. 2002 Jun;23(6):484-9. PMID: 12067772.12067772
31 Borg G. Perceived exertion as an indicator of somatic stress. Scand J Rehabil Med. 1970;2(2):92-8. PMID: 5523831.5523831
32 Simon PM, Schwartzstein RM, Weiss JW, . Distinguishable types of dyspnea in patients with shortness of breath. Am Rev Respir Dis. 1990 Nov;142(5):1009-14. doi: 10.1164/ajrccm/142.5.1009. PMID: 2240820.2240820
33 Powers J, Bennett SJ. Measurement of dyspnea in patients treated with mechanical ventilation. Am J Crit Care. 1999 Jul;8(4):254-61. PMID: 10392226.10392226
34 Parshall MB, Welsh JD, Brockopp DY, . Reliability and validity of dyspnea sensory quality descriptors in heart failure patients treated in an emergency department. Heart Lung 2001 Jan-Feb;30(1):57-65. doi: 10.1067/mhl.2001.112499. PMID: 11174368.11174368
35 Parshall MB. Psychometric characteristics of dyspnea descriptor ratings in emergency department patients with exacerbated chronic obstructive pulmonary disease. Res Nurs Health. 2002 Oct;25(5):331-44. doi: 10.1002/nur.10051. PMID: 12221688.12221688
36 Heyse-Moore L. On dysonoea in advanced cancer. South Hampton University; 1993.
37 Cedarbaum JM, Stambler N, Malta E, . The ALSFRS-R: a revised ALS functional rating scale that incorporates assessments of respiratory function. BDNF ALS Study Group (Phase III). J Neurol Sci. 1999 Oct 31;169(1-2):13-21. PMID: 10540002.10540002
38 Ferris B. Recommended respiratory disease questionnaire for use with adults and children in epidemiological research. American Review of Respiratory Disease. 1978;118:7-53.354446
39 Leidy NK, Schmier JK, Jones MK, . Evaluating symptoms in chronic obstructive pulmonary disease: validation of the Breathlessness, Cough and Sputum Scale. Respir Med. 2003 Jan;97 Suppl A:S59-70. PMID: 12564612.12564612
40 Guyatt GH, Nogradi S, Halcrow S, . Development and testing of a new measure of health status for clinical trials in heart failure. J Gen Intern Med 1989 Mar-Apr;4(2):101-7. PMID: 2709167.2709167
41 Lewin RJ, Thompson DR, Martin CR, . Validation of the Cardiovascular Limitations and Symptoms Profile (CLASP) in chronic stable angina. J Cardiopulm Rehabil 2002 May-Jun;22(3):184-91. PMID: 12042687.12042687
42 Selim AJ, Ren XS, Fincke G, . A symptom-based measure of the severity of chronic lung disease: results from the Veterans Health Study. Chest. 1997 Jun;111(6):1607-14. PMID: 9187183.9187183
43 Schunemann HJ, Griffith L, Jaeschke R, . A comparison of the original chronic respiratory questionnaire with a standardized version. Chest. 2003 Oct;124(4):1421-9. PMID: 14555575.14555575
44 Guyatt GH, Berman LB, Townsend M, . A measure of quality of life for clinical trials in chronic lung disease. Thorax. 1987 Oct;42(10):773-8. PMID: 3321537.3321537
45 Bergman B, Aaronson NK, Ahmedzai S, . The EORTC QLQ-LC13: a modular supplement to the EORTC Core Quality of Life Questionnaire (QLQ-C30) for use in lung cancer clinical trials. EORTC Study Group on Quality of Life. Eur J Cancer. 1994;30A(5):635-42. PMID: 8080679.8080679
46 Garrod R, Bestall JC, Paul EA, . Development and validation of a standardized measure of activity of daily living in patients with severe COPD: the London Chest Activity of Daily Living scale (LCADL). Respir Med. 2000 Jun;94(6):589-96. doi: 10.1053/rmed.2000.0786. PMID: 10921765.10921765
47 Dougan CF, Connell CO, Thornton E, . Development of a patient-specific dyspnoea questionnaire in motor neurone disease (MND): the MND dyspnoea rating scale (MDRS). J Neurol Sci. 2000 Nov 1;180(1-2):86-93. PMID: 11090871.11090871
48 Fairbairn AS, Wood CH, Fletcher CM. Variability in answers to a questionnaire on respiratory symptoms. Br J Prev Soc Med. 1959 Oct;13:175-93. PMID: 13821340.13821340
49 McGavin CR, Artvinli M, Naoe H, . Dyspnoea, disability, and distance walked: comparison of estimates of exercise performance in respiratory disease. Br Med J. 1978 Jul 22;2(6132):241-3. PMID: 678885.678885
50 Lareau SC, Carrieri-Kohlman V, Janson-Bjerklie S, . Development and testing of the Pulmonary Functional Status and Dyspnea Questionnaire (PFSDQ). Heart Lung 1994 May-Jun;23(3):242-50. PMID: 8039994.8039994
51 Rosenthal M, Lohr KN, Rubenstein RS, . Congestive heart failure. Santa Monica, CA: Rand Corporation; 1981.
52 Jones PW, Quirk FH, Baveystock CM, . A self-complete measure of health status for chronic airflow limitation. The St. George's Respiratory Questionnaire. Am Rev Respir Dis. 1992 Jun;145(6):1321-7. doi: 10.1164/ajrccm/145.6.1321. PMID: 1595997.1595997
53 Lee L, Friesen M, Lambert IR, . Evaluation of dyspnea during physical and speech activities in patients with pulmonary diseases. Chest. 1998 Mar;113(3):625-32. PMID: 9515835.9515835
54 Eakin EG, Resnikoff PM, Prewitt LM, . Validation of a new dyspnea measure: the UCSD Shortness of Breath Questionnaire. University of California, San Diego. Chest. 1998 Mar;113(3):619-24. PMID: 9515834.9515834
55 Abbey JG, Rosenfeld B, Pessin H, . Hopelessness at the end of life: the utility of the hopelessness scale with terminally ill cancer patients. Br J Health Psychol. 2006 May;11(Pt 2):173-83. doi: 10.1348/135910705x36749. PMID: 16643692.16643692
56 Ironson G, Solomon GF, Balbin EG, . The Ironson-woods Spirituality/Religiousness Index is associated with long survival, health behaviors, less distress, and low cortisol in people with HIV/AIDS. Ann Behav Med. 2002 Winter;24(1):34-48. PMID: 12008793.12008793
57 Love AW, Grabsch B, Clarke DM, . Screening for depression in women with metastatic breast cancer: a comparison of the Beck Depression Inventory Short Form and the Hospital Anxiety and Depression Scale. Aust N Z J Psychiatry. 2004 Jul;38(7):526-31. doi: 10.1111/j.1440-1614.2004.01385.x. PMID: 15255825.15255825
58 Akechi T, Okuyama T, Sugawara Y, . Major depression, adjustment disorders, and post-traumatic stress disorder in terminally ill cancer patients: associated and predictive factors. J Clin Oncol. 2004 May 15;22(10):1957-65. doi: 10.1200/jco.2004.08.149. PMID: 15143090.15143090
59 Thekkumpurath P, Venkateswaran C, Kumar M, . Screening for psychological distress in palliative care: performance of touch screen questionnaires compared with semistructured psychiatric interview. J Pain Symptom Manage. 2009 Oct;38(4):597-605. doi: 10.1016/j.jpainsymman.2009.01.004. PMID: 19692204.19692204
60 Lloyd-Williams M, Shiels C, Dowrick C. The development of the Brief Edinburgh Depression Scale (BEDS) to screen for depression in patients with advanced cancer. J Affect Disord. 2007 Apr;99(1-3):259-64. doi: 10.1016/j.jad.2006.09.015. PMID: 17055588.17055588
61 Okamura M, Yamawaki S, Akechi T, . Psychiatric disorders following first breast cancer recurrence: prevalence, associated factors and relationship to quality of life. Jpn J Clin Oncol. 2005 Jun;35(6):302-9. doi: 10.1093/jjco/hyi097. PMID: 15961434.15961434
62 Dumont S, Fillion L, Gagnon P, . A new tool to assess family caregivers' burden during end-of-life care. J Palliat Care. 2008 Autumn;24(3):151-61. PMID: 18942565.18942565
63 Cameron JI, Franche RL, Cheung AM, . Lifestyle interference and emotional distress in family caregivers of advanced cancer patients. Cancer. 2002 Jan 15;94(2):521-7. doi: 10.1002/cncr.10212. PMID: 11900237.11900237
64 Weitzner MA, McMillan SC, Jacobsen PB. Family caregiver quality of life: differences between curative and palliative cancer treatment settings. J Pain Symptom Manage. 1999 Jun;17(6):418-28. PMID: 10388247.10388247
65 Hudson PL, Hayman-White K. Measuring the psychosocial characteristics of family caregivers of palliative care patients: psychometric properties of nine self-report instruments. J Pain Symptom Manage. 2006 Mar;31(3):215-28. doi: 10.1016/j.jpainsymman.2005.07.010. PMID: 16563316.16563316
66 Hwang SS, Chang VT, Alejandro Y, . Caregiver unmet needs, burden, and satisfaction in symptomatic advanced cancer patients at a Veterans Affairs (VA) medical center. Palliat Support Care. 2003 Dec;1(4):319-29. PMID: 16594221.16594221
67 Cooper B, Kinsella GJ, Picton C. Development and initial validation of a family appraisal of caregiving questionnaire for palliative care. Psychooncology. 2006 Jul;15(7):613-22. doi: 10.1002/pon.1001. PMID: 16287207.16287207
68 Cohen R, Leis AM, Kuhl D, . QOLLTI-F: measuring family carer quality of life. Palliat Med. 2006 Dec;20(8):755-67. doi: 10.1177/0269216306072764. PMID: 17148530.17148530
69 Higginson IJ, Gao W, Jackson D, . Short-form Zarit Caregiver Burden Interviews were valid in advanced conditions. J Clin Epidemiol. 2010 May;63(5):535-42. doi: 10.1016/j.jclinepi.2009.06.014. PMID: 19836205.19836205
70 Rosenfeld B, Gibson C, Kramer M, . Hopelessness and terminal illness: the construct of hopelessness in patients with advanced AIDS. Palliat Support Care. 2004 Mar;2(1):43-53. PMID: 16594234.16594234
71 Nissim R, Flora DB, Cribbie RA, . Factor structure of the Beck Hopelessness Scale in individuals with advanced cancer. Psychooncology. 2010 Mar;19(3):255-63. doi: 10.1002/pon.1540. PMID: 19274620.19274620
72 Guarnaccia CA, B H. Factor structure of the bereavement experience questionnaire: the BEQ-24, a revised short-form. Omega. 1998;37:303-16.
73 Shear KM, Jackson CT, Essock SM, . Screening for complicated grief among Project Liberty service recipients 18 months after September 11, 2001. Psychiatr Serv. 2006 Sep;57(9):1291-7. doi: 10.1176/appi.ps.57.9.1291. PMID: 16968758.16968758
74 Ito M, Nakajima S, Fujisawa D, . Brief measure for screening complicated grief: reliability and discriminant validity. PLoS One. 2012;7(2):e31209. doi: 10.1371/journal.pone.0031209. PMID: 22348057.22348057
75 Fujisawa D, Miyashita M, Nakajima S, . Prevalence and determinants of complicated grief in general population. J Affect Disord. 2010 Dec;127(1-3):352-8. doi: 10.1016/j.jad.2010.06.008. PMID: 20580096.20580096
76 Burnett P, Middleton W, Raphael B, . Measuring core bereavement phenomena. Psychol Med. 1997 Jan;27(1):49-57. PMID: 9122308.9122308
77 Jordan JR, Baker J, Matteis M, . The grief evaluation measure (GEM): an initial validation study. Death Stud. 2005 May;29(4):301-32. doi: 10.1080/07481180590923706. PMID: 15849881.15849881
78 Barrett TW, Scott TB. Development of the Grief Experience Questionnaire. Suicide Life Threat Behav. 1989 Summer;19(2):201-15. PMID: 2749862.2749862
79 Hogan NS, Greenfield DB, Schmidt LA. Development and validation of the Hogan Grief Reaction Checklist. Death Stud 2001 Jan-Feb;25(1):1-32. doi: 10.1080/07481180125831. PMID: 11503760.11503760
80 Prigerson HG, Maciejewski PK, Reynolds CF, 3rd . Inventory of Complicated Grief: a scale to measure maladaptive symptoms of loss. Psychiatry Res. 1995 Nov 29;59(1-2):65-79. PMID: 8771222.8771222
81 Prigerson HG, Horowitz MJ, Jacobs SC, . Prolonged grief disorder: Psychometric validation of criteria proposed for DSM-V and ICD-11. PLoS Med. 2009 Aug;6(8):e1000121. doi: 10.1371/journal.pmed.1000121. PMID: 19652695.19652695
82 O'Connor M, Lasgaard M, Shevlin M, . A confirmatory factor analysis of combined models of the Harvard Trauma Questionnaire and the Inventory of Complicated Grief-Revised: are we measuring complicated grief or posttraumatic stress? J Anxiety Disord. 2010 Oct;24(7):672-9. doi: 10.1016/j.janxdis.2010.04.009. PMID: 20510576.20510576
83 Guldin MB, O'Connor M, Sokolowski I, . Identifying bereaved subjects at risk of complicated grief: Predictive value of questionnaire items in a cohort study. BMC Palliat Care. 2011;10:9. doi: 10.1186/1472-684x-10-9. PMID: 21575239.21575239
84 Prigerson HG, SC J. Traumatic grief as a distinct disorder: a rationale, consensus criteria, and a preliminary empirical test. In: Stroebe MS, Hansson RO, Stroebe W, . (eds) Handbook of bereavement research: consequences, coping, and care. Washington, DC: American Psychological Association; 2001.
85 Marwit SJ, Meuser TM. Development and initial validation of an inventory to assess grief in caregivers of persons with Alzheimer's disease. Gerontologist. 2002 Dec;42(6):751-65. PMID: 12451156.12451156
86 Marwit SJ, Kaye PN. Measuring grief in caregivers of persons with acquired brain injury. Brain Inj. 2006 Dec;20(13-14):1419-29. PMID: 17378234.17378234
87 Marwit SJ, Chibnall JT, Dougherty R, . Assessing pre-death grief in cancer caregivers using the Marwit-Meuser Caregiver Grief Inventory (MM-CGI). Psychooncology. 2008 Mar;17(3):300-3. doi: 10.1002/pon.1218. PMID: 17518412.17518412
88 Marwit SJ, Meuser TM. Development of a short form inventory to assess grief in caregivers of dementia patients. Death Stud. 2005 Apr;29(3):191-205. doi: 10.1080/07481180590916335. PMID: 15816111.15816111
89 Kiely DK, Prigerson H, Mitchell SL. Health care proxy grief symptoms before the death of nursing home residents with advanced dementia. Am J Geriatr Psychiatry. 2008 Aug;16(8):664-73. doi: 10.1097/JGP.0b013e3181784143. PMID: 18669945.18669945
90 Lai C, Luciani M, Morelli E, . Predictive role of different dimensions of burden for risk of complicated grief in caregivers of terminally ill patients. Am J Hosp Palliat Care. 2014 Mar;31(2):189-93. doi: 10.1177/1049909113490227. PMID: 23689368.23689368
91 Lichtenthal WG, Nilsson M, Kissane DW, . Underutilization of mental health services among bereaved caregivers with prolonged grief disorder. Psychiatr Serv. 2011 Oct;62(10):1225-9. doi: 10.1176/appi.ps.62.10.122510.1176/ps.62.10.pss6210_1225. PMID: 21969652.21969652
92 Papa A, Lancaster NG, Kahler J. Commonalities in grief responding across bereavement and non-bereavement losses. J Affect Disord. 2014 Jun;161:136-43. doi: 10.1016/j.jad.2014.03.018. PMID: 24751321.24751321
93 Lev E, Munro BH, McCorkle R. A shortened version of an instrument measuring bereavement. Int J Nurs Stud. 1993 Jun;30(3):213-26. PMID: 8335431.8335431
94 Faschingbauer T, DeVaul RA, S Z. The Texas Revised Inventory of Grief. In: Zisook S (ed.) Biopsychosocial aspects of bereavement. Washington, DC: American Psychiatric Press, Inc.; 1987.
95 Zisook S, Devaul RA, Click MA, Jr. Measuring symptoms of grief and bereavement. Am J Psychiatry. 1982 Dec;139(12):1590-3. doi: 10.1176/ajp.139.12.1590. PMID: 7149059.7149059
96 Faschingbauer TR, Devaul RA, Zisook S. Development of the Texas Inventory of Grief. Am J Psychiatry. 1977 Jun;134(6):696-8. doi: 10.1176/ajp.134.6.696. PMID: 869041.869041
97 Futterman A, Holland JM, Brown PJ, . Factorial validity of the Texas Revised Inventory of Grief-Present scale among bereaved older adults. Psychol Assess. 2010 Sep;22(3):675-87. doi: 10.1037/a0019914. PMID: 20822280.20822280
98 Rubin SS, Nadav OB, Malkinson R, . The two-track model of bereavement questionnaire (TTBQ): development and validation of a relational measure. Death Stud. 2009 Apr;33(4):305-33. doi: 10.1080/07481180802705668. PMID: 19368062.19368062
99 Assessing complicated grief using the Two-Track Bereavement Questionnaire (TTBQ). The 10th international conference on Grief and Bereavement in Contemporary Society: East meets West expanding frontiers and diversity; 2014 Hong Kong. p. 54.
100 Guo H, Fine PG, Mendoza TR, . A preliminary study of the utility of the brief hospice inventory. J Pain Symptom Manage. 2001 Aug;22(2):637-48. PMID: 11495710.11495710
101 Ewing G, Todd C, Rogers M, . Validation of a symptom measure suitable for use among palliative care patients in the community: CAMPAS-R. J Pain Symptom Manage. 2004 Apr;27(4):287-99. doi: 10.1016/j.jpainsymman.2003.12.012. PMID: 15050656.15050656
102 Kissane DW, Wein S, Love A, . The Demoralization Scale: a report of its development and preliminary validation. J Palliat Care. 2004 Winter;20(4):269-76. PMID: 15690829.15690829
103 Kaasa T, Loomis J, Gillis K, . The Edmonton Functional Assessment Tool: preliminary development and evaluation for use in palliative care. J Pain Symptom Manage. 1997 Jan;13(1):10-9. PMID: 9029857.9029857
104 Kaasa T, Wessel J. The Edmonton Functional Assessment Tool: further development and validation for use in palliative care. J Palliat Care. 2001 Spring;17(1):5-11. PMID: 11324186.11324186
105 Schwartz CE, Merriman MP, Reed GW, . Measuring patient treatment preferences in end-of-life care research: applications for advance care planning interventions and response shift research. J Palliat Med. 2004 Apr;7(2):233-45. doi: 10.1089/109662104773709350. PMID: 15130201.15130201
106 Blazeby JM, Conroy T, Hammerlid E, . Clinical and psychometric validation of an EORTC questionnaire module, the EORTC QLQ-OES18, to assess quality of life in patients with oesophageal cancer. Eur J Cancer. 2003 Jul;39(10):1384-94. PMID: 12826041.12826041
107 Blazeby JM, Conroy T, Bottomley A, . Clinical and psychometric validation of a questionnaire module, the EORTC QLQ-STO 22, to assess quality of life in patients with gastric cancer. Eur J Cancer. 2004 Oct;40(15):2260-8. doi: 10.1016/j.ejca.2004.05.023. PMID: 15454251.15454251
108 Chang VT, Hwang SS, Feuerman M. Validation of the Edmonton Symptom Assessment Scale. Cancer. 2000 May 1;88(9):2164-71. PMID: 10813730.10813730
109 Lyons KD, Bakitas M, Hegel MT, . Reliability and validity of the Functional Assessment of Chronic Illness Therapy-Palliative care (FACIT-Pal) scale. J Pain Symptom Manage. 2009 Jan;37(1):23-32. doi: 10.1016/j.jpainsymman.2007.12.015. PMID: 18504093.18504093
110 McMillan SC, Weitzner M. Quality of life in cancer patients: use of a revised Hospice Index. Cancer Pract 1998 Sep-Oct;6(5):282-8. PMID: 9767348.9767348
111 McMillan SC, Dunbar SB, W Z. Validation of the Hospice Quality-of-Life Index and the Constipation Assessment Scale in end-stage cardiac disease patients in hospice care. J Hosp Palliat Nurs. 2008;10:106-17.
112 Dobratz MC. The life closure scale: additional psychometric testing of a tool to measure psychological adaptation in death and dying. Res Nurs Health. 2004 Feb;27(1):52-62. doi: 10.1002/nur.20003. PMID: 14745856.14745856
113 Salmon P, Manzi F, Valori RM. Measuring the meaning of life for patients with incurable cancer: the life evaluation questionnaire (LEQ). Eur J Cancer. 1996 May;32A(5):755-60. PMID: 9081350.9081350
114 Sterkenburg CA, King B, Woodward CA. A reliability and validity study of the McMaster Quality of Life Scale (MQLS) for a palliative population. J Palliat Care. 1996 Spring;12(1):18-25. PMID: 8857243.8857243
115 Cohen SR, Mount BM, Bruera E, . Validity of the McGill Quality of Life Questionnaire in the palliative care setting: a multi-centre Canadian study demonstrating the importance of the existential domain. Palliat Med. 1997 Jan;11(1):3-20. PMID: 9068681.9068681
116 Cohen SR, Mount BM. Living with cancer: “good” days and “bad” days--what produces them? Can the McGill quality of life questionnaire distinguish between them? Cancer. 2000 Oct 15;89(8):1854-65. PMID: 11042583.11042583
117 Lua PL, Salek S, Finlay I, . The feasibility, reliability and validity of the McGill Quality of Life Questionnaire-Cardiff Short Form (MQOL-CSF) in palliative care population. Qual Life Res. 2005 Sep;14(7):1669-81. PMID: 16119179.16119179
118 McCanse RP. The McCanse Readiness for Death Instrument (MRDI): a reliable and valid measure for hospice care. Hosp J. 1995;10(1):15-26. PMID: 7789938.7789938
119 Sherman DW, Ye XY, Beyer McSherry C, . Symptom assessment of patients with advanced cancer and AIDS and their family caregivers: the results of a quality-of-life pilot study. Am J Hosp Palliat Care 2007 Oct-Nov;24(5):350-65. doi: 10.1177/1049909106299063. PMID: 17998406.17998406
120 Lobchuk MM. The memorial symptom assessment scale: modified for use in understanding family caregivers' perceptions of cancer patients' symptom experiences. J Pain Symptom Manage. 2003 Jul;26(1):644-54. PMID: 12850647.12850647
121 Chang VT, Hwang SS, Kasimis B, . Shorter symptom assessment instruments: the Condensed Memorial Symptom Assessment Scale (CMSAS). Cancer Invest. 2004;22(4):526-36. PMID: 15565810.15565810
122 Hickman SE, Tilden VP, Tolle SW. Family reports of dying patients' distress: the adaptation of a research tool to assess global symptom distress in the last week of life. J Pain Symptom Manage. 2001 Jul;22(1):565-74. PMID: 11516598.11516598
123 Byock IR, Merriman MP. Measuring quality of life for patients with terminal illness: the Missoula-VITAS quality of life index. Palliat Med. 1998 Jul;12(4):231-44. PMID: 9743822.9743822
124 Schwartz CE, Merriman MP, Reed G, . Evaluation of the Missoula-VITAS Quality of Life Index--revised: research tool or clinical tool? J Palliat Med. 2005 Feb;8(1):121-35. doi: 10.1089/jpm.2005.8.121. PMID: 15662181.15662181
125 Rainbird KJ, Perkins JJ, Sanson-Fisher RW. The Needs Assessment for Advanced Cancer Patients (NA-ACP): a measure of the perceived needs of patients with advanced, incurable cancer. a study of validity, reliability and acceptability. Psychooncology. 2005 Apr;14(4):297-306. doi: 10.1002/pon.845. PMID: 15386766.15386766
126 Vernooij-Dassen MJ, Osse BH, Schade E, . Patient autonomy problems in palliative care: systematic development and evaluation of a questionnaire. J Pain Symptom Manage. 2005 Sep;30(3):264-70. doi: 10.1016/j.jpainsymman.2005.03.010. PMID: 16183010.16183010
127 Chochinov HM, Hassard T, McClement S, . The patient dignity inventory: a novel way of measuring dignity-related distress in palliative care. J Pain Symptom Manage. 2008 Dec;36(6):559-71. doi: 10.1016/j.jpainsymman.2007.12.018. PMID: 18579340.18579340
128 Osse BH, Vernooij MJ, Schade E, . Towards a new clinical tool for needs assessment in the palliative care of cancer patients: the PNPC instrument. J Pain Symptom Manage. 2004 Oct;28(4):329-41. doi: 10.1016/j.jpainsymman.2004.01.010. PMID: 15471650.15471650
129 Osse BH, Vernooij-Dassen MJ, Schade E, . A practical instrument to explore patients' needs in palliative care: the Problems and Needs in Palliative Care questionnaire short version. Palliat Med. 2007 Jul;21(5):391-9. doi: 10.1177/0269216307078300. PMID: 17901098.17901098
130 Hearn J, Higginson IJ. Development and validation of a core outcome measure for palliative care: the palliative care outcome scale. Palliative Care Core Audit Project Advisory Group. Qual Health Care. 1999 Dec;8(4):219-27. PMID: 10847883.10847883
131 Steinhauser KE, Clipp EC, Bosworth HB, . Measuring quality of life at the end of life: validation of the QUAL-E. Palliat Support Care. 2004 Mar;2(1):3-14. PMID: 16594230.16594230
132 Hermann C. Development and testing of the spiritual needs inventory for patients near the end of life. Oncol Nurs Forum. 2006 Jul;33(4):737-44. doi: 10.1188/06.onf.737-744. PMID: 16858454.16858454
133 Arcand M, Monette J, Monette M, . Educating nursing home staff about the progression of dementia and the comfort care option: impact on family satisfaction with end-of-life care. J Am Med Dir Assoc. 2009 Jan;10(1):50-5. doi: 10.1016/j.jamda.2008.07.008. PMID: 19111853.19111853
134 Baker R, Wu AW, Teno JM, . Family satisfaction with end-of-life care in seriously ill hospitalized adults. J Am Geriatr Soc. 2000 May;48(5 Suppl):S61-9. PMID: 10809458.10809458
135 Bakitas M, Ahles TA, Skalla K, . Proxy perspectives regarding end-of-life care for persons with cancer. Cancer. 2008 Apr 15;112(8):1854-61. doi: 10.1002/cncr.23381. PMID: 18306393.18306393
136 Cohen LW, van der Steen JT, Reed D, . Family perceptions of end-of-life care for long-term care residents with dementia: differences between the United States and the Netherlands. J Am Geriatr Soc. 2012 Feb;60(2):316-22. doi: 10.1111/j.1532-5415.2011.03816.x. PMID: 22288500.22288500
137 Gelfman LP, Meier DE, Morrison RS. Does palliative care improve quality? A survey of bereaved family members. J Pain Symptom Manage. 2008 Jul;36(1):22-8. doi: 10.1016/j.jpainsymman.2007.09.008. PMID: 18411019.18411019
138 Hallenbeck J, Hickey E, Czarnowski E, . Quality of care in a Veterans Affairs' nursing home-based hospice unit. J Palliat Med. 2007 Feb;10(1):127-35. doi: 10.1089/jpm.2006.0141. PMID: 17298261.17298261
139 Shega JW, Hougham GW, Stocking CB, . Patients dying with dementia: experience at the end of life and impact of hospice care. J Pain Symptom Manage. 2008 May;35(5):499-507. doi: 10.1016/j.jpainsymman.2007.06.011. PMID: 18261878.18261878
140 Teno JM, Clarridge B, Casey V, . Validation of Toolkit After-Death Bereaved Family Member Interview. J Pain Symptom Manage. 2001 Sep;22(3):752-8. PMID: 11532588.11532588
141 Kiely DK, Volicer L, Teno J, . The validity and reliability of scales for the evaluation of end-of-life care in advanced dementia. Alzheimer Dis Assoc Disord 2006 Jul-Sep;20(3):176-81. PMID: 16917188.16917188
142 van der Steen JT, Gijsberts MJ, Muller MT, . Evaluations of end of life with dementia by families in Dutch and U.S. nursing homes. Int Psychogeriatr. 2009 Apr;21(2):321-9. doi: 10.1017/s1041610208008399. PMID: 19193253.19193253
143 Alici Y, Smith D, Lu HL, . Families' perceptions of veterans' distress due to post-traumatic stress disorder-related symptoms at the end of life. J Pain Symptom Manage. 2010 Mar;39(3):507-14. doi: 10.1016/j.jpainsymman.2009.07.011. PMID: 20083372.20083372
144 Casarett D, Shreve S, Luhrs C, . Measuring families' perceptions of care across a health care system: preliminary experience with the Family Assessment of Treatment at End of Life Short form (FATE-S). J Pain Symptom Manage. 2010 Dec;40(6):801-9. doi: 10.1016/j.jpainsymman.2010.03.019. PMID: 20813493.20813493
145 Finlay E, Shreve S, Casarett D. Nationwide veterans affairs quality measure for cancer: the family assessment of treatment at end of life. J Clin Oncol. 2008 Aug 10;26(23):3838-44. doi: 10.1200/jco.2008.16.8534. PMID: 18688050.18688050
146 Lu H, Trancik E, Bailey FA, . Families' perceptions of end-of-life care in Veterans Affairs versus non-Veterans Affairs facilities. J Palliat Med. 2010 Aug;13(8):991-6. doi: 10.1089/jpm.2010.0044. PMID: 20649437.20649437
147 Smith D, Caragian N, Kazlo E, . Can we make reports of end-of-life care quality more consumer-focused? results of a nationwide quality measurement program. J Palliat Med. 2011 Mar;14(3):301-7. doi: 10.1089/jpm.2010.0321. PMID: 21288125.21288125
148 Connor SR, Teno J, Spence C, . Family evaluation of hospice care: results from voluntary submission of data via website. J Pain Symptom Manage. 2005 Jul;30(1):9-17. doi: 10.1016/j.jpainsymman.2005.04.001. PMID: 16043002.16043002
149 Mitchell SL, Kiely DK, Miller SC, . Hospice care for patients with dementia. J Pain Symptom Manage. 2007 Jul;34(1):7-16. doi: 10.1016/j.jpainsymman.2007.01.003. PMID: 17509813.17509813
150 Rhodes RL, Mitchell SL, Miller SC, . Bereaved family members' evaluation of hospice care: what factors influence overall satisfaction with services? J Pain Symptom Manage. 2008 Apr;35(4):365-71. doi: 10.1016/j.jpainsymman.2007.12.004. PMID: 18294811.18294811
151 Rhodes RL, Teno JM, Connor SR. African American bereaved family members' perceptions of the quality of hospice care: lessened disparities, but opportunities to improve remain. J Pain Symptom Manage. 2007 Nov;34(5):472-9. doi: 10.1016/j.jpainsymman.2007.06.004. PMID: 17900854.17900854
152 Schockett ER, Teno JM, Miller SC, . Late referral to hospice and bereaved family member perception of quality of end-of-life care. J Pain Symptom Manage. 2005 Nov;30(5):400-7. doi: 10.1016/j.jpainsymman.2005.04.013. PMID: 16310614.16310614
153 Teno JM, Clarridge BR, Casey V, . Family perspectives on end-of-life care at the last place of care. JAMA. 2004 Jan 7;291(1):88-93. doi: 10.1001/jama.291.1.88. PMID: 14709580.14709580
154 Teno JM, Shu JE, Casarett D, . Timing of referral to hospice and quality of care: length of stay and bereaved family members' perceptions of the timing of hospice referral. J Pain Symptom Manage. 2007 Aug;34(2):120-5. doi: 10.1016/j.jpainsymman.2007.04.014. PMID: 17583469.17583469
155 York GS, Jones JL, Churchman R. Understanding the association between employee satisfaction and family perceptions of the quality of care in hospice service delivery. J Pain Symptom Manage. 2009 Nov;38(5):708-16. doi: 10.1016/j.jpainsymman.2009.03.002. PMID: 19699608.19699608
156 Curtis JR, Treece PD, Nielsen EL, . Integrating palliative and critical care: evaluation of a quality-improvement intervention. Am J Respir Crit Care Med. 2008 Aug 1;178(3):269-75. doi: 10.1164/rccm.200802-272OC. PMID: 18480429.18480429
157 Gries CJ, Curtis JR, Wall RJ, . Family member satisfaction with end-of-life decision making in the ICU. Chest. 2008 Mar;133(3):704-12. doi: 10.1378/chest.07-1773. PMID: 18198256.18198256
158 Lewis-Newby M, Curtis JR, Martin DP, . Measuring family satisfaction with care and quality of dying in the intensive care unit: does patient age matter? J Palliat Med. 2011 Dec;14(12):1284-90. doi: 10.1089/jpm.2011.0138. PMID: 22107108.22107108
159 Aoun S, Bird S, Kristjanson LJ, . Reliability testing of the FAMCARE-2 scale: measuring family carer satisfaction with palliative care. Palliat Med. 2010 Oct;24(7):674-81. doi: 10.1177/0269216310373166. PMID: 20621947.20621947
160 Carter GL, Lewin TJ, Gianacas L, . Caregiver satisfaction with out-patient oncology services: utility of the FAMCARE instrument and development of the FAMCARE-6. Support Care Cancer. 2011 Apr;19(4):565-72. doi: 10.1007/s00520-010-0858-1. PMID: 20349317.20349317
161 Lo C, Burman D, Hales S, . The FAMCARE-Patient scale: measuring satisfaction with care of outpatients with advanced cancer. Eur J Cancer. 2009 Dec;45(18):3182-8. doi: 10.1016/j.ejca.2009.09.003. PMID: 19786345.19786345
162 Lo C, Burman D, Rodin G, . Measuring patient satisfaction in oncology palliative care: psychometric properties of the FAMCARE-patient scale. Qual Life Res. 2009 Aug;18(6):747-52. doi: 10.1007/s11136-009-9494-y. PMID: 19513815.19513815
163 Ringdal GI, Jordhoy MS, Kaasa S. Measuring quality of palliative care: psychometric properties of the FAMCARE Scale. Qual Life Res. 2003 Mar;12(2):167-76. PMID: 12639063.12639063
164 Follwell M, Burman D, Le LW, . Phase II study of an outpatient palliative care intervention in patients with metastatic cancer. J Clin Oncol. 2009 Jan 10;27(2):206-13. doi: 10.1200/jco.2008.17.7568. PMID: 19064979.19064979
165 Kristjanson LJ, Leis A, Koop PM, . Family members' care expectations, care perceptions, and satisfaction with advanced cancer care: results of a multi-site pilot study. J Palliat Care. 1997 Winter;13(4):5-13. PMID: 9447806.9447806
166 Meyers JL, Gray LN. The relationships between family primary caregiver characteristics and satisfaction with hospice care, quality of life, and burden. Oncol Nurs Forum 2001 Jan-Feb;28(1):73-82. PMID: 11198900.11198900
167 Mularski R, Curtis JR, Osborne M, . Agreement among family members in their assessment of the Quality of Dying and Death. J Pain Symptom Manage. 2004 Oct;28(4):306-15. doi: 10.1016/j.jpainsymman.2004.01.008. PMID: 15471648.15471648
168 Hales S, Gagliese L, Nissim R, . Understanding bereaved caregiver evaluations of the quality of dying and death: an application of cognitive interviewing methodology to the quality of dying and death questionnaire. J Pain Symptom Manage. 2012 Feb;43(2):195-204. doi: 10.1016/j.jpainsymman.2011.03.018. PMID: 21802895.21802895
169 Johnson KS, Elbert-Avila K, Kuchibhatla M, . Racial differences in next-of-kin participation in an ongoing survey of satisfaction with end-of-life care: a study of a study. J Palliat Med. 2006 Oct;9(5):1076-85. doi: 10.1089/jpm.2006.9.1076. PMID: 17040145.17040145
170 Mularski RA, Heine CE, Osborne ML, . Quality of dying in the ICU: ratings by family members. Chest. 2005 Jul;128(1):280-7. doi: 10.1378/chest.128.1.280. PMID: 16002947.16002947
171 Norris K, Merriman MP, Curtis JR, . Next of kin perspectives on the experience of end-of-life care in a community setting. J Palliat Med. 2007 Oct;10(5):1101-15. doi: 10.1089/jpm.2006.2546. PMID: 17985967.17985967
172 Astrow AB, Wexler A, Texeira K, . Is failure to meet spiritual needs associated with cancer patients' perceptions of quality of care and their satisfaction with care? J Clin Oncol. 2007 Dec 20;25(36):5753-7. doi: 10.1200/jco.2007.12.4362. PMID: 18089871.18089871
173 Sulmasy DP, McIlvane JM. Patients' ratings of quality and satisfaction with care at the end of life. Arch Intern Med. 2002 Oct 14;162(18):2098-104. PMID: 12374518.12374518
174 Sulmasy DP, McIlvane JM, Pasley PM, . A scale for measuring patient perceptions of the quality of end-of-life care and satisfaction with treatment: the reliability and validity of QUEST. J Pain Symptom Manage. 2002 Jun;23(6):458-70. PMID: 12067770.12067770
175 National Quality Forum. National voluntary consensus standards for symptom management and end-of-life care in cancer patients. 2006. http://www.qualityforum.org. Accessed May 9, 2016.
176 Hospital Quality Reporting. Baltimore, MD: Centers for Medicare & Medicaid Services; 2015. https://www.cms.gov/Medicare/Quality-Initiatives-Patient-Assessment-Instruments/Hospice-Quality-Reporting/index.html. Accessed October 28, 2016.
177 Hospice Item Set (HIS). Baltimore, MD: Centers for Medicare & Medicaid Services; 2016. https://www.cms.gov/Medicare/Quality-Initiatives-Patient-Assessment-Instruments/Hospice-Quality-Reporting/Hospice-Item-Set-HIS.html. Accessed October 28, 2016.
178 COSMIN: consensus-based standards for the selection of health measurement instruments. Vrije Universiteit Medisch Centrum http://www.cosmin.nl/ Accessed August 19, 2016.