# Methods

## Engagement with Key Informants

We recruited Key Informants to give a balanced perspective on different domains, and applications of palliative care tools in providing guidance for our work. Key Informants included clinicians providing palliative care, leading palliative care assessment tool researchers, and caregivers for patients who had received palliative care. We conducted telephone meetings with the Key Informants to explore their perspectives related to assessment tools, particularly their beliefs regarding the efficacy and applicability of existing tools. We conducted two one and one-half hour-long meetings with the Key Informants: one call for caregivers, and one for clinicians/researchers. (See Appendix C for Key Informant questions.) Two team members reviewed the recordings and notes from the calls to identify themes.

## Systematic Review Search

We searched for English-language systematic reviews using Cochrane, PubMed, CINAHL, PsycINFO, and PsycTESTS. (Detailed search strategies are available in Appendix D.) The search was conducted through August 29, 2016. We also screened the Palliative Care Research Cooperative Group (PCRC) list of reviews.^14^ In our searches, we included all age groups, populations, and settings, but selected tools relevant to care in the U.S. We searched for reviews published within the last 10 years, because the PEACE systematic review was completed in 2007. We followed Evidence-based Practice Center (EPC) Program guidelines for the use of existing systematic reviews^15^ and assessed the quality of relevant systematic reviews using the Risk of Bias in Systematic Reviews (ROBIS) tool.^16^ Paired team members independently screened search results to select (1) systematic reviews describing palliative care assessment tools and their properties, and (2) systematic reviews on the use of palliative care assessment tools for the three applications of clinical practice, quality indicators, and evaluation of interventions. For each domain or subdomain and application, we chose one systematic review using these criteria: relevance, dual ROBIS quality assessment (Appendix E), the date of publication, and the availability of evidence tables.

## Supplemental Search

We conducted supplemental searches for domains or subdomains that either (a) did not have a systematic review published within the last ten years or (b) had a systematic review with a search completed greater than three years ago. (See Appendix F for search flow of systematic review and supplemental searches.) Our supplemental search included:

1. Three comprehensive reviews of tools:
  a. The TIME Toolkit of Instruments to Measure End-of-Life Care^6^
  b. The systematic review for the National Institutes of Health State of the Science Conference on Improving End-of-Life Care ^9-10^
  c. The PEACE Palliative Care Quality Measures project^11,17^
2. Web sites of compiled lists and databases of published palliative care tools:
  a. University of Washington End-of-Life Care Research Program Instruments^18^
  b. City of Hope Pain & Palliative Care Resource Center^19^
  c. National Palliative Care Research Center Measurement and Evaluation Tools^20^
  d. Center for Research on End-of-Life Care^22^
3. If we identified no tools through the above approaches, we conducted a targeted search in PubMed to identify primary literature on palliative care assessment tools addressing the specific domain or subdomain (Inclusion criteria used for the search can be found in Appendix G).

Since our supplemental searches did not include peer-reviewed data on tool characteristics, such as validity or reliability, we did not abstract those characteristics. Tools identified in the supplemental searches are summarized in the Appendices (Appendix J, Evidence Table 1).

## Data Organization

We used the National Consensus Project Clinical Practice Guidelines for Quality Palliative Care domains along with a ninth domain of “multidimensional tools” as a conceptual framework (Figure 1). We abstracted information from selected existing systematic reviews based on key elements from the National Quality Forum criteria for Patient Reported Outcomes in Performance Measurement,^17^ developed by an expert panel and are based on scientific acceptability (i.e., validity, reliability, and responsiveness ) and usability (i.e., verification that the tool has been used, is feasible, and provides useful information for palliative care in the areas of clinical practice, quality indicators, or evaluation of interventions).

## Peer Review and Public Commentary

A draft version of this Technical Brief was posted for peer review on August 19, 2016, and we revised the report in response to reviewer comments.