# Introduction

## Background

Palliative care is defined as care that provides relief from pain and other symptoms and supports quality of life for patients with serious advanced illness and their families.^1^ Over the last decade, a multi-professional group published consensus guidelines that define the domains that palliative care should address (Figure 1).^2^ Because palliative care is fundamentally concerned with the patient/caregiver experience, the best way to assess these domains involves patient and/or caregiver reports. Therefore, valid and responsive patient and caregiver assessment tools addressing all domains are essential to measuring the quality and effectiveness of palliative care.

Figure 1 Conceptualization of domains and applications of palliative care assessment tools

^1^ Dying in America: Improving Quality and Honoring Individual Preferences Near the End of Life. Washington DC: National Academy of Sciences; 2015.

^2^ As adapted from: National Consensus Project for Quality Palliative Care. Clinical Practice Guidelines for Quality Palliative Care, Third Edition. 2015. http://www.nationalconsensusproject.org. Accessed on December 1, 2015.

Figure 1 is a conceptual description of palliative care assessment tools, categorized by the eight domains defined within the National Consensus Project Guidelines along with an additional domain identified as “multidimensional.” This Domain incorporates the sub-domains of quality-of-life, and patient experience.

We defined an assessment tool as a data collection instrument (generally a scale, questionnaire or survey) that has been psychometrically evaluated, is completed by or with patients or caregivers, and collects data at the individual patient or caregiver level (see Appendix A for Glossary). Assessment tools may include patient and caregiver reports of physical symptoms (e.g., pain and dyspnea), mental health issues (e.g., depression), caregiver outcomes (e.g., quality of life and burden), and processes of care (e.g., communication and continuity). For conceptual ease, palliative care assessment tools can be categorized by the eight domains defined within the National Consensus Project Guidelines (Figure 1)^2^ as well as by a ninth domain for palliative care assessment tools that are innately multidimensional (i.e., tools that assess quality of life or patient experience). The multidimensional domain tools include items that cross multiple domains and often address areas such as physical health and functional status, mental health, social and role function, as well as physical and psychological symptoms (i.e., Edmonton Symptom Assessment Score,^3^ Memorial Symptom Assessment Score,^4^ etc.). Each of the domains may also have subdomains, such as the subdomains of pain, dyspnea, or fatigue which are within the over-arching physical domain.

Palliative care assessment tools may be used for varying applications within palliative care. Assessment tools may be used by providers in clinical care to directly assess symptoms or other issues with patients or families. Assessment tools may also be used as quality indicators, defined as population-based measures that enable users to quantify the quality of an aspect of care by comparing it to evidence-based criteria.^5^ Finally, assessment tools may be used in research studies to evaluate the impact of a specific palliative care intervention(s).

Exploration of assessment tools across three applications – clinical, quality indicators, and intervention - is important because a tool's utility may vary by its application. For example, measuring aspects of care important for research-related, academic inquiry may not be important, or even feasible, in clinical care delivery. Assessment tools to be primarily used in clinical care settings are optimally simple and brief to facilitate ease of completion by a seriously ill patient and/or a frequently-overwhelmed family member. In contrast, assessment tools to be used primarily to evaluate interventions may be lengthier and/or specific to targeted intervention-related domains of palliative care; when optimal, these tools are both highly responsive (sensitive to change) and reliable to facilitate detection of intervention-related outcome variations.

Ultimately, palliative care assessment tools should be reliable, valid, and responsive assessments of aspects of care that are important to patients and caregivers.^6^ These tools should also be particularly responsive to palliative care interventions as well as easily administered in palliative care populations and settings.^7^ Given these goals, researchers and others seeking to improve the quality of palliative care face two challenges (1) determining whether there are sufficient tools to address all palliative care domains and applications, and (2) determining, for each domain and application, which tools are the most appropriate for use as determined by reliability, validity, and responsiveness.

Over the past 15 years, various groups have published compilations of palliative care assessment tools to try to address the challenges of measurement. In the mid-1990s, Teno et al. published a Toolkit of Instruments to Measure End-of-Life Care (TIME).8 (See Appendix B for a list of acronyms.) In 2004, for the National Institutes of Health State of the Science Conference on Improving End-of-Life Care,9 the End of Life Care and Outcomes systematic review10 updated the TIME review and summarized the psychometric properties of 99 additional, relevant assessment tools and their use in assessing palliative care interventions.11, 12 The PEACE Palliative Care Quality Measures project then updated the End of Life Care and Outcomes review through February 2007 and reported on a select number of tools.13

Since the PEACE project in 2007, no reviews have addressed the use of assessment tools across palliative care domains, although additional tools have been developed and applied in these domains. Subsequent systematic reviews have addressed a few individual domains and some multidimensional domains (e.g., quality of life); however, these reviews have not been synthesized into a comprehensive overview of the field. Given that these tools are frequently used together or overlap in measured concepts, and given the growth of the field of palliative care in clinical scope and research over the past ten years, an integrated overview of assessment tools is valuable. This overview would also: identify domains that lack sufficient assessment tools; highlight areas for future research; and provide a resource for individuals choosing tools for use in clinical care, quality indicators, or intervention settings.

## Objectives of This Technical Brief

Our objectives are to provide a comprehensive overview of palliative care assessment tools that could be used by stakeholders interested in the use of palliative care assessment tools for application in clinical care, as quality indicators, or for evaluation of interventions. We also sought to identify evidence gaps and suggest next steps for future research about palliative care assessment tools.

## Guiding Questions

Our work was guided by the following questions:

Guiding Question 1: In each of the palliative care domains, what palliative care assessment tools exist and have been evaluated in palliative care populations and/or settings?

Guiding Question 2: What is the state of current research on the reliability, validity, responsiveness, and usability of these assessment tools?

Guiding Question 3: What data exist regarding the application of these tools specifically in clinical care, as quality indicators, or for evaluation of interventions?

Guiding Question 4: What are the key gaps in tool development and evaluation and what are the opportunities for future research?