# Peer Reviewers

Prior to publication of the final evidence report, we sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. We worked with the Task Order Officer to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Betty Ferrell, Ph.D., M.A, FAAN, FPCN
  City of Hope
  Duarte, CA
- Jean Kutner, M.D., M.S.P.H.
  University of Colorado School of Medicine
  Aurora, CO
- Jeri L. Miller, Ph.D.
  NIH, National Institute of Nursing Research
  Bethesda, MD
- Jennifer Temel, M.D.
  Massachusetts General Hospital
  Boston, MA
- Deborah Waldrop, Ph.D., M.S.W.
  University of Buffalo
  Buffalo, NY