# Key Informants

In designing the study questions, we consulted a panel of Key Informants that represented subject experts and end-users of research. Key Informant input can inform key issues related to the topic of the technical brief. Key Informants are not involved in the analysis of the evidence nor the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. We worked with the Task Order Officer to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Karen A. Armacost, M.S.A., R.N.^*^
  Caregiver Advocate
  Baltimore, MD
- Marie Bakitas, D.N.Sc, C.R.N.P.^*^
  University of Alabama at Birmingham
  School of Nursing & Department of Medicine
  Birmingham, AL
- Dena Battle
  Caregiver Advocate
  Alexandria, VA
- Eduardo Bruera, M.D.^*^
  The University of Texas
  M.D. Anderson Cancer Center
  Houston, TX
- J. Randall Curtis, M.D., M.P.H.^*^
  University of Washington
  UW Medicine
  Seattle, WA
- Steven Z. Pantilat, M.D.^*^
  University of California, San Francisco
  San Francisco, CA
- Holly G. Prigerson, Ph.D.^*^
  Cornell University
  Weill Cornell Medical College
  New York, NY
- Joan Teno, M.D., M.S.^*^
  University of Washington
  Seattle, WA
- Joanne Wolfe, M.D., M.P.H.^*^
  Dana Farber Cancer Institute
  Boston, MA

* This Key Informant also provided review of the draft report