# Acknowledgments

We gratefully acknowledge the following individuals for their contributions to this project: Dio Kavalieratos, Ph.D., and Dara Ikejiani for their assistance with the section about evaluation of interventions; Jennifer Wolff, Ph.D., and Karl Lorenz, M.D., M.H.S., for their input on specific results sections; and Jeanette Edelstein, M.A., for her copy editing service.