# Appendix J Evidence Tables

Evidence Table 1 Tools identified in the supplemental searches

Domain | Website/Review | URL | Tools
Structure and process of care | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | McCusker 4-item instrument for continuity
Structure and process of care | End of Life Care and Outcomes Systematic Review | http://onlinelibrary.wiley.com/doi/10.1111/j.1475-6773.2007.00721.x/abstract | Quality of communication questionnaire
Physical Pain | The City of Hope Pain & Palliative Care Resource Center | http://prc.coh.org/res inst.asp and subsite search: http://prc.coh.org/pain assessment.asp (Tools only address pain and dyspnea) | MD Anderson Symptom Inventory
Physical Pain | The City of Hope Pain & Palliative Care Resource Center | http://prc.coh.org/res inst.asp and subsite search: http://prc.coh.org/pain assessment.asp (Tools only address pain and dyspnea) | Family Pain Questionnaire
Physical Pain | The City of Hope Pain & Palliative Care Resource Center | http://prc.coh.org/res inst.asp and subsite search: http://prc.coh.org/pain assessment.asp (Tools only address pain and dyspnea) | Patient Pain Interview
Physical Pain | The City of Hope Pain & Palliative Care Resource Center | http://prc.coh.org/res inst.asp and subsite search: http://prc.coh.org/pain assessment.asp (Tools only address pain and dyspnea) | Patient Pain Questionnaire
Physical Pain | The City of Hope Pain & Palliative Care Resource Center | http://prc.coh.org/res inst.asp and subsite search: http://prc.coh.org/pain assessment.asp (Tools only address pain and dyspnea) | Psychosocial Pain Assessment Form
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | The Breakthrough Pain Questionnaire
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Brief Pain Inventory
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | City of Hope Mayday Pain Resource Center Pain Audit Tools
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | City of Hope Mayday Pain Resource Center Patient Pain Questionnaire
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Descriptor Differential Scale
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Integrated Pain Score
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | McGill Pain Questionnaire
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Memorial Pain Assessment Card
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Numerical Rating Scale for Pain
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Pain as assessed in the Medical Outcomes Study
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Pain Disability Index
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Pain Management Index
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Pain Perception Profile
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Patient Outcome Questionnaire
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Cancer Total Quality Pain Management Patient Assessment Tool (TQPM)
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Unmet Analgesic Needs Questionnaire
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Verbal Rating Scale for Pain
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Visual Analogue Scale for Pain
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | West Haven-Yale Multidimensional Pain Inventory
Physical Pain | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Wisconsin Brief Pain Questionnaire
Physical Fatigue | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Epworth Sleepiness Scale (ESS)
Physical Fatigue | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Fatigue Questionnaire (FQ)
Physical Fatigue | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Fatigue Symptom Inventory (FSI)
Physical Fatigue | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Fatigue Severity Scale (FSS)
Physical Fatigue | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Multidimensional Fatigue Symptoms Inventory (MFSI)
Physical Fatigue | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Piper Fatigue Scale
Physical Fatigue | The National Palliative Care Research Center Measurement and Evaluation Tools | http://www.npcrc.org/content/25/Measurement-and-Evaluation-Tools.aspx | Brief Fatigue Inventory
Psychological and psychiatric | The City of Hope Pain & Palliative Care Resource Center | http://prc.coh.org/res_inst.asp | World Health Organization (WHO) (Five) Well-Being Index (http://www.who-5.org/)
Psychological and psychiatric | The National Palliative Care Research Center Measurement and Evaluation Tools | http://www.npcrc.org/content/25/Measurement-and-Evaluation-Tools.aspx | Geriatric Depression Scale (long and short form)
Psychological and psychiatric | The National Palliative Care Research Center Measurement and Evaluation Tools | http://www.npcrc.org/content/25/Measurement-and-Evaluation-Tools.aspx | Hamilton Depression Scale (http://www.npcrc.org/files/news/hamilton_depression_scale.pdf)
Psychological and psychiatric | The National Palliative Care Research Center Measurement and Evaluation Tools | http://www.npcrc.org/content/25/Measurement-and-Evaluation-Tools.aspx | Scales of Psychological Well-Being
Psychological and psychiatric | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Center for Epidemiologic Studies Depression Scale (CES-D)
Psychological and psychiatric | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Impact of Event Scale (IES)
Psychological and psychiatric | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Mental Health Inventory
Psychological and psychiatric | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | PASS Pain Anxiety Symptoms Scale
Psychological and psychiatric | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Profile of Mood States
Psychological and psychiatric | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Present State Examination (PSE)
Psychological and psychiatric | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Reactions to the Diagnosis of Cancer Questionnaire (RDCQ)
Psychological and psychiatric | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Self-rating Depression Scale
Psychological and psychiatric | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | The Symptom Questionnaire (SQ)
Psychological and psychiatric | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | State-Trait Anxiety Inventory (STAI)
Psychological and psychiatric | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Starck Scale
Psychological and psychiatric | Toolkit of Instruments to Measure End-of-Life Care (TIME) | https://nts122.chcr.brown.edu/pcoc/BIBLIOGRAPHIES.HTM | Symptom Anxiety and Depression Scale
Psychological and psychiatric | End of Life Care and Outcomes Systematic Review | http://onlinelibrary.wiley.com/doi/10.1111/j.1475-6773.2007.00721.x/abstract | Cornell Scale for Depression in Dementia
Psychological and psychiatric | PEACE Palliative Care Quality Measures project | http://www.med.unc.edu/pcare/files/assessment-instruments-for-end-of-life-care | PRIME-MD / PHQ-9
Ethical and legal aspects of care | End of Life Care and Outcomes Systematic Review | http://onlinelibrary.wiley.com/doi/10.1111/j.1475-6773.2007.00721.x/abstract | Relatives' patient management questionnaire
Ethical and legal aspects of care | End of Life Care and Outcomes Systematic Review | http://onlinelibrary.wiley.com/doi/10.1111/j.1475-6773.2007.00721.x/abstract | Willingness to Accept Life-sustaining Treatment instrument (WALT)

CES-D=Center for Epidemiologic Studies Depression Scale; PHQ-9= Patient Health Queationnaire-9; PRIME-MD=Primary Care Evaluation of Mental Disorders; PSE=Present State Examination; RDCQ=Reactions to the Diagnosis of Cancer Questionnaire; SQ=The Symptom Questionnaire; STAI=State-Trait Anxiety Inventory; TIME=Toolkit of Instruments to Measure End-of-Life Care; TQPM=Cancer Total Quality Pain Management Patient Assessment Tool; WALT=Willingness to Accept Life-Sustaining Treatment Instrument; WHO=World Health Organization

Evidence Table 2a Characteristics of the selected review, Dorman, 2007^2^ addressing the physical domain (subdomain, dyspnea)

Author, year of systematic review/website | Review focus – NCP domain, tool (and definition if relevant), population, setting | Inclusion criteria | Number of tools included (number of studies) | Years of search (range)
Dorman, 2007^2^ | Breathlessness, physical aspects of care | Patient-based scales for either clinical or research purposes and evaluation of at least two psychometric properties | 29 (30 studies), 26 included in this report | Up to 2005

NCP=National Consensus Project for Quality Palliative Care Clinical Practice

Evidence Table 2b Population and setting of tools included in the selected review, Dorman, 2007^2^ addressing the physical domain (subdomain, dyspnea)

Author, year, of individual study(s) within the review for each tool | Instrument (s) (Full name and abbreviation) | Population (s) | Setting where testing results are reported from
Gift, 1989^3^ | Visual analogue scale (HVAS and VVAS) | Asthma, COPD, ventilated | ED, outpatient, inpatient, ITU, Pulmonary rehab, coronary care unit
Gift, 1998^4^ Tanaka, 2002^5^ | Numeric rating scale (NRS) or Dyspnea Numeric Scale | Cancer, COPD | Outpatient, home
Borg, 1982^6^ Borg, 1970^7^ | Modified Borg Scale (mBORG) | COPD, restrictive lung disease, asthma | Outpatient
Simon, 1990^8^ | Global shortness of breath question (Global SOB) | COPD | Outpatient, randomized controlled trial
Powers, 1999^9^ | Faces scale (Faces) | Ventilated | Coronary care unit, intensive therapy unit
Parshall, 2001^10^ | Dyspnea Descriptor Questionnaire (heart failure); DDQ (heart failure) | Heart failure | ED
Parshall, 2002^11^ | Dyspnea Descriptor Questionnaire (COPD); DDQ (COPD) | COPD | ED
Heyse-Moore, 1993^12^ | Dyspnea Assessment Questionnaire (DAQ) | Cancer | Hospice
Cedarbaum, 1999^13^ | Amyotrophic lateral sclerosis functional rating scale – revised, respiratory subscale (ALSFRS-R) | MND (Motor Neuron Disease) | Trial
Ferris, 1978^14^ | American Thoracic Society Division of Lung Diseases 1978 Dyspnea Scale (ATS-DLD-78) | COPD, asthma | Outpatient
Leidy, 2003^15^ | Breathlessness, Cough and Sputum Scale, breathlessness subscale (BCSS) | COPD | RCT
Guyatt, 1989^16^ | Chronic Heart Failure Questionnaire – dyspnea subscale (CHQ-D) | Heart failure | Outpatient, RCT
Lewin, 2002^17^ | Cardiovascular Limitations and Symptoms Profile (CLASP) | Ischemic heart disease | Outpatient
Selim, 1997^18^ | Chronic Lung Disease Severity Index (CLD) | Chronic lung disease | Outpatient
Guyatt, 1987^19^ | Chronic Respiratory Questionnaire – dyspnea subscale (CRQ-D, CRQ-SAI-D) | COPD, interstitial lung disease, cystic fibrosis, alpha antitrypsin deficiency, MND | Outpatient, inpatient, pulmonary rehabilitation, RCT
Schunemann, 2003^20^ | CRQ Standardized dyspnea questions (CRQ-SAS-D, CRQ-IAS-D) | N | N
Bergman, 1994^21^ | European Organization for Research and Treatment of Cancer Quality of Life Questionnaire Lung Cancer supplement, breathlessness subscale (EORTC-QLQ; LC13 breathlessness) | Lung cancer | RCT
Garrod, 2000^22^ | London Chest Activity of Daily Living Scale (LCADL) | COPD | Outpatient, home
Dougan, 2000^23^ | Motor Neurone Disease Dyspnea Rating Scale, dyspnea subscale (MDRS-D) | MND | Outpatient
Fairburn, 1959^24^ | Medical Research Council Dyspnea Scale (MRC) | COPD, interstitial lung disease, asthma, other | Outpatient
McGavin, 1978^25^ | Oxygen cost diagram (OCD) | Respiratory disease, COPD, heart failure | Outpatient
Lareau, 1994^26^ | Pulmonary Functional Status and Dyspnea Questionnaire-modified (PFSDQ-M) | COPD | Pulmonary rehabilitation
Rosenthal, 1981^27^ | Rand Instrument: shortness of breath battery from the Medical History Questionnaire (Rand) | Heart failure, respiratory disease | Outpatient
Jones, 1992^28^ | St George's Respiratory Questionnaire (activity subscale) (SGRO) | COPD, asthma, bronchiectasis | Outpatient, pulmonary rehabilitation
Lee, 1998^29^ | University of Cincinnati Dyspnea Questionnaire (UCDQ) | Asthma, sarcoid, COPD, fibrosis | Outpatient, exercise lab
Eakin, 1998^30^ | University of California San Diego Shortness of Breath Questionnaire (UCSD SOBQ) | COPD, asthma, cystic fibrosis, lung transplant | Pulmonary rehabilitation, outpatient

ALSFRS-R =Amyotrophic lateral sclerosis functional rating scale – revised; ATS-DLD-78=American Thoracic Society Division of Lung Diseases 1978 Dyspnea Scale; BCSS =Breathlessness, Cough and Sputum Scale; CHQ-D =Chronic Heart Failure Questionnaire – dyspnea subscale; CLASP =Cardiovascular Limitations and Symptoms Profile; CLD =Chronic Lung Disease Severity Index; COPD=chronic obstructive pulmonary disease; CRQ-D, CRQ-SAI-D =Chronic Respiratory Questionnaire – dyspnea subscale; CRQ-SAS-D, CRQ-IAS-D =CRQ Standardized dyspnea questions; DAQ =Dyspnea Assessment Questionnaire; DDQ (COPD)=Dyspnea Descriptor Questionnaire (COPD); DDQ =Dyspnea Descriptor Questionnaire (heart failure); ED=emergency department; EORTC-QLQ =European Organization for Research and Treatment of Cancer Quality of Life Questionnaire; Faces =Faces scale; Global SOB =Global shortness of breath question; ITU=intensive therapy unit; LC13 breathlessness=Lung Cancer supplement, breathlessness subscale; LCADL =London Chest Activity of Daily Living Scale; mBORG =Modified Borg Scale; MDRS-D =Motor Neurone Disease Dyspnea Rating Scale; MND=motor neurone disease; MRC =Medical Research Council Dyspnea Scale; N=not present in the primary article; NR=not reported in the systematic review or on the website; NRS=Numeric rating scale; OCD =Oxygen cost diagram; PFSDQ-M =Pulmonary Functional Status and Dyspnea Questionnaire-modified; Rand =Rand Instrument: shortness of breath battery from the Medical History Questionnaire; RCT=randomized controlled trial; SGRO =St George's Respiratory Questionnaire (activity subscale); UCDQ =University of Cincinnati Dyspnea Questionnaire; UCSD SOBQ =University of California San Diego Shortness of Breath Questionnaire; VAS=Visual analogue scale

Evidence Table 2c Domain characteristics of tools included in the selected review, Dorman, 2007^2^ addressing the physical domain (subdomain, dyspnea)

Author, year, of individual study(s) within the review for each tool | Instrument | Domain (from NCP national guidelines) | Subdomains of NCP domain addressed (eg, pain, dyspnea) | Sub-scales
Gift, 1989^3^ | VAS | Physical | Dyspnea | N
Gift, 1998^4^ Tanaka, 2002^5^ | NRS or dyspnea numeric scale | Physical | Dyspnea | N
Borg, 1982^7^ | mBORG | Physical | Dyspnea | N
Simon,1990^8^ | Global SOB | Physical | Dyspnea | N
Powers, 1999^9^ | Faces | Physical | Dyspnea | N
Parshall, 2001^10^ | DDQ heart failure | Physical | Dyspnea | N
Parshall, 2002^11^ | DDQ COPD | Physical | Dyspnea | N
Heyse-Moore, 1993^12^ | DAQ | Physical | Dyspnea | N
Cedarbaum, 1999^13^ | ALSFRS-R | Physical | Dyspnea | Respiratory subscale
Ferris, 1978^14^ | ATS-DLD-78 | Physical | Dyspnea | N
Leidy, 2003^15^ | BCSS | Physical | Dyspnea | Breathlessness subscale
Guyatt, 1989^16^ | CHQ-D | Physical | Dyspnea | Dyspnea subscale
Lewin, 2002^17^ | CLASP | Physical | Dyspnea | N
Selim, 1997^18^ | CLD | Physical | Dyspnea | N
Guyatt, 1987^19^ | CRQ-D, CRQ-SAI-D | Physical | Dyspnea | Dyspnea subscale
Schunemann, 2003^20^ | CRQ-SAS-D, CRQ-IAS-D | Physical | Dyspnea | N
Bergman, 1994^21^ | EORTC-QLQ; LC13 breathlessness | Physical | Dyspnea | Breathlessness subscale
Garrod, 2000^22^ | LCADL | Physical | Dyspnea | N
Dougan, 2000^23^ | MDRS-D | Physical | Dyspnea | Dyspnea subscale
Fairburn, 1959^24^ | MRC | Physical | Dyspnea | N
McGavin, 1978^25^ | OCD | Physical | Dyspnea | N
Lareau, 1994^26^ | PFSDQ-M | Physical | Dyspnea | N
Rosenthal, 1981^27^ | MHQ, Rand subscale | Physical | Dyspnea | N
Jones, 1992^28^ | SGRO | Physical | Dyspnea | Activity subscale
Lee, 1998^29^ | UCDQ | Physical | Dyspnea | N
Eakin, 1998^30^ | UCSD SOBQ | Physical | Dyspnea | N

ALSFRS-R =Amyotrophic lateral sclerosis functional rating scale – revised; ATS-DLD-78=American Thoracic Society Division of Lung Diseases 1978 Dyspnea Scale; BCSS =Breathlessness, Cough and Sputum Scale; CHQ-D =Chronic Heart Failure Questionnaire – dyspnea subscale; CLASP =Cardiovascular Limitations and Symptoms Profile; CLD =Chronic Lung Disease Severity Index; CRQ-D, CRQ-SAI-D =Chronic Respiratory Questionnaire – dyspnea subscale; CRQ-SAS-D, CRQ-IAS-D =CRQ Standardized dyspnea questions; DAQ =Dyspnea Assessment Questionnaire; DDQ (COPD)=Dyspnea Descriptor Questionnaire (COPD); DDQ =Dyspnea Descriptor Questionnaire (heart failure); EORTC-QLQ =European Organization for Research and Treatment of Cancer Quality of Life Questionnaire; Faces =Faces scale; Global SOB =Global shortness of breath question; LC13 breathlessness=Lung Cancer supplement, breathlessness subscale; LCADL =London Chest Activity of Daily Living Scale; mBORG =Modified Borg Scale; MDRS-D =Motor Neurone Disease Dyspnea Rating Scale; MRC =Medical Research Council Dyspnea Scale; N=not present in the primary article; ND=no data available (review did not abstract);; NR=not reported in the systematic review or on the website; NRS=Numeric rating scale; OCD =Oxygen cost diagram; PFSDQ-M =Pulmonary Functional Status and Dyspnea Questionnaire-modified; Rand =Rand Instrument: shortness of breath battery from the Medical History Questionnaire; SGRO =St George's Respiratory Questionnaire (activity subscale); UCDQ =University of Cincinnati Dyspnea Questionnaire; UCSD SOBQ =University of California San Diego Shortness of Breath Questionnaire; VAS=Visual analogue scale; Y=present in the primary article

Evidence Table 2d Measurement characteristics of tools included in the selected review, Dorman, 2007^2^ addressing the physical domain (subdomain, dyspnea)

Author, year, of individual study(s) within the review for each tool | Instrument (abbreviation) | Form completed by | Mode of administration | Number of items | Completion time (usability)
Gift, 1989^3^ | Visual analogue scale | N | ND | 1 | Y^*^
Gift, 1998^4^ Tanaka, 2002^5^ | Numeric rating scale or dyspnea numeric scale | N | ND | 1 | Y^*^
Borg, 1982^7^ | Modified Borg Scale | N | ND | 1 | Y^*^
Simon,1990^8^ | Global shortness of breath question | N | ND | 1 | N
Powers, 1999^9^ | Faces scale | Patient | ND | 1 | N
Parshall, 2001^10^ | DDQ (heart failure) | N | ND | 13 | N
Parshall, 2002^11^ | DDQ (COPD) | N | ND | 16 (reduced to 7) | N
Heyse-Moore, 1993^12^ | (DAQ) | Patient | ND | 43 | N
Cedarbaum, 1999^13^ | (ALSFRS-R) | N | ND | 3 | N
Ferris, 1978^14^ | (ATS-DLD-78) | N | ND | 5 | Y^*^
Leidy, 2003^15^ | (BCSS) | N | ND | 1 | N
Guyatt, 1989^16^ | (CHQ-D) | Patient | ND | 5 | Y^*^
Lewin, 2002^17^ | (CLASP) | N | ND | 6 | Y^*^
Selim, 1997^18^ | (CLD) | N | ND | 2 | N
Guyatt, 1987^19^ | (CRQ-D, CRQ-SAI-D) | Patient | ND | 5 (out of 25) | Y^*^
Schunemann, 2003^20^ | (CRQ-SAS-D, CRQ-IAS-D) | Patient | ND | 5 | N
Bergman, 1994^21^ | (EORTC-QLQ; LC13 breathlessness) | N | ND | 3 | N
Garrod, 2000^22^ | (LCADL) | N | ND | 15 | N
Dougan, 2000^23^ | (MDRS-D) | Patient | ND | 5 (out of 13) | Y^*^
Fairburn, 1959^24^ | (MRC) | N | ND | 1 | Y^*^
McGavin, 1978^25^ | (OCD) | Patient | ND | 1 | Y^*^
Lareau, 1994^26^ | (PFSDQ-M) | N | ND | 5 | Y^*^
Rosenthal, 1981^27^ | (MHQ, Rand subscale) | N | ND | 9 | Y^*^
Jones, 1992^28^ | (SGRO) | N | ND | 16 | Y^*^
Lee, 1998^29^ | (UCDQ) | N | ND | 30 | Y^*^
Eakin, 1998^30^ | (UCSD SOBQ) | N | ND | 24 | Y^*^

ALSFRS-R =Amyotrophic lateral sclerosis functional rating scale – revised; ATS-DLD-78=American Thoracic Society Division of Lung Diseases 1978 Dyspnea Scale; BCSS =Breathlessness, Cough and Sputum Scale; CHQ-D =Chronic Heart Failure Questionnaire – dyspnea subscale; CLASP =Cardiovascular Limitations and Symptoms Profile; CLD =Chronic Lung Disease Severity Index; CRQ-D, CRQ-SAI-D =Chronic Respiratory Questionnaire – dyspnea subscale; CRQ-SAS-D, CRQ-IAS-D =CRQ Standardized dyspnea questions; DAQ =Dyspnea Assessment Questionnaire; DDQ (COPD)=Dyspnea Descriptor Questionnaire (COPD); DDQ =Dyspnea Descriptor Questionnaire (heart failure); EORTC-QLQ =European Organization for Research and Treatment of Cancer Quality of Life Questionnaire; Faces =Faces scale; Global SOB =Global shortness of breath question; LC13 breathlessness=Lung Cancer supplement, breathlessness subscale; LCADL =London Chest Activity of Daily Living Scale; mBORG =Modified Borg Scale; MDRS-D =Motor Neurone Disease Dyspnea Rating Scale; MRC =Medical Research Council Dyspnea Scale; N=not present in the primary article;; ND=no data available (review did not abstract);; NR=not reported in the systematic review or on the website; NRS=Numeric rating scale; OCD =Oxygen cost diagram; PFSDQ-M =Pulmonary Functional Status and Dyspnea Questionnaire-modified; Rand =Rand Instrument: shortness of breath battery from the Medical History Questionnaire; SGRO =St George's Respiratory Questionnaire (activity subscale); UCDQ =University of Cincinnati Dyspnea Questionnaire; UCSD SOBQ =University of California San Diego Shortness of Breath Questionnaire; VAS=Visual analogue scale; Y=present in the primary article

* The review noted completion time (usability) was available for the tool, but did not state what that completion time is.

Evidence Table 2e Psychometric properties of tools included in the selected review, Dorman, 2007^2^ addressing the physical domain (subdomain, dyspnea)

Author, year, of individual study(s) within the review for each tool | Instrument abbreviation | Reliability: Internal consistency (Total score if present) | Test-retest reliability | Inter-rater reliability | Construct validity | Specific construct validity results: discriminant, criterion) | Sensitivity to change/responsiveness
Gift, 1989^3^ | Visual analogue scale | ND | Y | ND | Y | Y | N
Gift, 1998^4^ Tanaka, 2002^5^ | Numeric rating scale or dyspnea numeric scale | ND | Y | ND | Y | Y | N
Borg, 1982^7^ | Modified Borg Scale | ND | Y | ND | Y | Y | N
Simon, 1990^8^ | Global shortness of breath question | ND | N | ND | Y | N | Y
Powers, 1999^9^ | Faces scale | ND | Y | ND | Y | N | N
Parshall, 2001^10^ | DDQ (heart failure) | Y | Y | ND | N | N | N
Parshall, 2002^11^ | DDQ (COPD) | Y | Y | ND | N | N | N
Heyse-Moore, 1993^12^ | DAQ | N | N | ND | Y | N | N
Cedarbaum, 1999^13^ | ALSFRS-R | Y | N | ND | Y | N | N
Ferris, 1978^14^ | ATS-DLD-78 | Y | Y | ND | Y | N | N
Leidy, 2003^15^ | BCSS | ND | Y | ND | Y | Y | Y
Guyatt, 1989^16^ | CHQ-D | Y | Y | ND | Y | Y | Y
Lewin, 2002^17^ | (CLASP) | N | Y | ND | Y | N | N
Selim, 1997^18^ | (CLD) | Y | N | ND | Y | N | N
Guyatt, 1987^19^ | (CRQ-D, CRQ-SAI-D) | Y | Y | ND | Y | Y | Y
Schunemann, 2003^20^ | (CRQ-SAS-D, CRQ-IAS-D) | ND | ND | ND | ND | ND | ND
Bergman, 1994^21^ | (EORTC-QLQ; LC13 breathlessness) | Y | Y | ND | Y | Y | N
Garrod, 2000^22^ | (LCADL) | Y | Y | ND | Y | Y | N
Dougan, 2000^23^ | (MDRS-D) | Y | N | ND | Y | N | N
Fairburn, 1959^24^ | Scale (MRC) | N | N | ND | Y | Y | N
McGavin, 1978^25^ | OCD | ND | Y | ND | Y | N | Y
Lareau, 1994^26^ | PFSDQ-M | Y | Y | ND | Y | Y | N
Rosenthal, 1981^27^ | MHQ, Rand subscale | N | Y | ND | Y | N | Y
Jones, 1992^28^ | SGRO | Y | Y | ND | Y | Y | Y
Lee, 1998^29^ | UCDQ | Y | Y | ND | Y | N | N
Eakin, 1998^30^ | UCSD SOBQ | Y | Y | ND | Y | N | Y

ALSFRS-R =Amyotrophic lateral sclerosis functional rating scale – revised; ATS-DLD-78=American Thoracic Society Division of Lung Diseases 1978 Dyspnea Scale; BCSS =Breathlessness, Cough and Sputum Scale; CHQ-D =Chronic Heart Failure Questionnaire – dyspnea subscale; CLASP =Cardiovascular Limitations and Symptoms Profile; CLD =Chronic Lung Disease Severity Index; CRQ-D, CRQ-SAI-D =Chronic Respiratory Questionnaire – dyspnea subscale; CRQ-SAS-D, CRQ-IAS-D =CRQ Standardized dyspnea questions; DAQ =Dyspnea Assessment Questionnaire; DDQ (COPD)=Dyspnea Descriptor Questionnaire (COPD); DDQ =Dyspnea Descriptor Questionnaire (heart failure); EORTC-QLQ =European Organization for Research and Treatment of Cancer Quality of Life Questionnaire; Faces =Faces scale; Global SOB =Global shortness of breath question; LC13 breathlessness=Lung Cancer supplement, breathlessness subscale; LCADL =London Chest Activity of Daily Living Scale; mBORG =Modified Borg Scale; MDRS-D =Motor Neurone Disease Dyspnea Rating Scale; MRC =Medical Research Council Dyspnea Scale; N=not present in the primary article;; ND=no data available (review did not abstract); NRS=Numeric rating scale; OCD =Oxygen cost diagram; PFSDQ-M =Pulmonary Functional Status and Dyspnea Questionnaire-modified; Rand =Rand Instrument: shortness of breath battery from the Medical History Questionnaire; SGRO =St George's Respiratory Questionnaire (activity subscale); UCDQ =University of Cincinnati Dyspnea Questionnaire; UCSD SOBQ =University of California San Diego Shortness of Breath Questionnaire; VAS=Visual analogue scale; Y=present in the primary article

Evidence Table 3a Characteristics of the selected review, Ziegler, 2011^31^ addressing psychosocial and psychiatric care domain

Author, year of systematic review/website | Review focus – NCP domain, tool (and definition if relevant), population, setting | Inclusion criteria | Number of tools in the review and number included (number of studies) | Years of search (range)
Ziegler, 2011^31^ | Psychosocial, Self-report measures of psychological distress, Cancer patients, Hospitals/hospices/primary care | Exploring the validation of a self-report measure alongside a structured clinical interview for psychiatric disorder | 48 tools (85 studies) – 8 tools (6 studies) focusing on psychosocial domain in palliative care populations | 1960 to unspecified end date

NCP=National Consensus Project for Quality Palliative Care Clinical Practice

Evidence Table 3b Population and setting of tools included in the selected review, Ziegler, 2011^31^ addressing psychosocial and psychiatric care domain

Author, year, of individual study(s) within the review for each tool | Instrument (s) (Full name and abbreviation) | Population (s) | Setting where testing results are reported from
Love, 2004^32^ | Hospital Anxiety and Depression Scale (HADS) | Metastatic breast cancer patients with recurrence | N
Akechi, 2004^33^ | Two single items: Are you depressed? and Have you lost interest? | Palliative care population | Palliative care unit
Thekkumpurath, 2009^34^ | Distress Thermometer (via touch screen) | Patients with advanced disease | inpatient or outpatient care
Thekkumpurath, 2009^34^ | Brief Symptom Inventory-18 | Patients with advanced disease | inpatient or outpatient care
Thekkumpurath, 2009^34^ | General Health Questionnaire-12 item (GHQ-12 ) | Patients with advanced disease | inpatient or outpatient care
Lloyd-Williams, 2007^35^ | Brief Edinburgh Depression Scale | Palliative care patients with a prognosis of six months or less | N
Love, 2004^32^ | Beck Depression Inventory-Short Form | Metastatic breast cancer patients with recurrence | N
Okamura, 2005^36^ | Mental Adjustment to Cancer | Patients at first recurrence of breast cancer | N

GHQ-12 =General Health Questionnaire-12 item; HADS =Hospital Anxiety and Depression Scale; N=not present in the primary article

(Note that some studies were listed more than once; in that case, the study validating in the broadest population and that had psychometrics was abstracted. All results were similar)

Evidence Table 3c Domain characteristics of tools included in the selected review, Ziegler, 2011^31^ addressing psychosocial and psychiatric care domain

Author, year, of relevant individual study(s) within the review for each tool | Instrument | Domain (from NCP national guidelines) | Subdomains of NCP domain addressed (eg, pain, dyspnea) | Subscales
Love, 2004^32^ | Hospital Anxiety and Depression Scale (HADS) | Psychosocial | Anxiety, depression | 2 subscales
Akechi, 2004^33^ | Two single items: Are you depressed? and Have you lost interest? | Psychosocial | Depression | N
Thekkumpurath, 2009^34^ | Distress Thermometer (via touch screen) | Psychosocial | Distress | N
Thekkumpurath, 2009^34^ | Brief Symptom Inventory-18 (via touch screen) | Psychosocial | Depression, anxiety, somatoform | 3 subscales
Thekkumpurath, 2009^34^ | General Health Questionnaire-12 item (GHQ-12 ) | Psychosocial | Distress | N
Lloyd-Williams, 2007^35^ | Brief Edinburgh Depression Scale | Psychosocial | Depression | N
Love, 2004^32^ | Beck Depression Inventory-Short Form | Psychosocial | Depression | N
Okamura, 2005^36^ | Mental Adjustment to Cancer | Psychosocial | Psychological response to having cancer | 5 subscales

GHQ-12 =General Health Questionnaire-12 item; HADS =Hospital Anxiety and Depression Scale; N=not present in the primary article

Evidence Table 3d Measurement characteristics of tools included in the selected review, Ziegler, 2011^31^ addressing psychosocial and psychiatric care domain

Author, year, of relevant individual study(s) within the review for each tool | Instrument (abbreviation) | Form completed by | Mode of administration | Number of items | Completion time (usability)
Love, 2004^32^ | Hospital Anxiety and Depression Scale (HADS) | Patient | Paper | 14 | 5 minutes
Akechi, 2004^33^ | Two single items: Are you depressed? and Have you lost interest? | Patient | Paper | 2 | Approximately 1-2 minutes
Thekkumpurath, 2009^34^ | Distress Thermometer | Patient | Touch screen | 1 | Approximately 1 minute
Thekkumpurath, 2009^34^ | Brief Symptom Inventory-18 | Patient | Touch screen | 18 | Approximately 10 minutes
Thekkumpurath, 2009^34^ | General Health Questionnaire-12 item (GHQ-12 ) | Patient | Touch screen | 12 | 5 minutes
Lloyd-Williams, 2007^35^ | Brief Edinburgh Depression Scale | Patient | N | 6 | Approximately 3 minutes
Love, 2004^32^ | Beck Depression Inventory-Short Form | Patient | N | 13 | Approximately 5-10 minutes
Okamura, 2005^36^ | Mental Adjustment to Cancer | Patient | N | 40 | N

GHQ-12 =General Health Questionnaire-12 item; HADS =Hospital Anxiety and Depression Scale; N=not present in the primary article

Evidence Table 3e Psychometric properties of tools included in the selected review, Ziegler, 2011^31^ addressing psychosocial and psychiatric care domain

Author, year, of individual study(s) within the review for each tool | Instrument | Reliability: Internal consistency (Total score if present) | Test-retest reliability | Inter-rater reliability | Convergent validity (Type of construct validity) | Specific additional construct validity types: discriminant, criterion | Sensitivity to change/responsiveness
Love, 2004^32^ | Hospital Anxiety and Depression Scale (HADS) | N | ND | ND | Y | ND | N
Akechi, 2004^33^ | Two single items: Are you depressed? and Have you lost interest? | N | ND | ND | Y | ND | N
Thekkumpurath, 2009^34^ | Distress Thermometer | N | ND | ND | Y | ND | N
Thekkumpurath, 2009^34^ | Brief Symptom Inventory-18 | N | ND | ND | Y | ND | N
Thekkumpurath, 2009^34^ | General Health Questionnaire-12 item (GHQ-12 ) | N | ND | ND | Y | ND | N
Lloyd-Williams, 2007^35^ | Brief Edinburgh Depression Scale | Y | ND | ND | Y | ND | N
Love, 2004^32^ | Beck Depression Inventory-Short Form | N | ND | ND | Y | ND | N
Okamura, 2005^36^ | Mental Adjustment to Cancer | N | ND | ND | N | ND | N

GHQ-12 =General Health Questionnaire-12 item; HADS =Hospital Anxiety and Depression Scale; N=not present in the primary article; ND=no data available (review did not abstract); Y=present in the primary article

Evidence Table 4a Characteristics of the selected review, Michels, 2016^37^ addressing the social domain

Author, year of systematic review/website | Review focus – NCP domain, tool (and definition if relevant), population, setting | Inclusion criteria | Number of tools in the review and number included (number of studies) | Years of search (range)
Michels, 2016^37^ | Social support, caregivers | Used a self-reported multidimensional measure that assessed caregiver outcomes; measures were directed at unpaid informal carers; patients were diagnosed with an advanced progressive illness or were receiving palliative care; both carers and patients were ⩾ 18years old; the study was reported in English. | 38 tools (112 studies); only 8 tools were included (8 studies abstracted) that are specifically related to palliative care in the US. | Not explicitly reported

NCP=National Consensus Project for Quality Palliative Care Clinical Practice

Evidence Table 4b Population and setting of tools included in the selected review, Michels, 2016^37^ addressing the social domain

Author, year, of individual study(s) within the review for each tool | Instrument (s) (Full name and abbreviation) | Population (s) | Setting where testing results are reported from
Dumont, 2008^38^ | Caregiver's Burden Scale in end-of-life care (CBS-EOLC) | Family caregivers of terminal cancer patients | ND
Cameron, 2002^39^ | Caregiver Impact Scale (CIS) | Caregivers of advanced cancer patients | ND
Weitzner, 1999^40^ | Caregiver Quality of Life Index – Cancer (CQOLI-C)^*^ | Caregivers of cancer | ND
Hudson, 2006^41^ | Caregiver Reaction Assessment (CRA) | Caregivers of patients receiving palliative care | ND
Hwang, 2003^42^ | Caregiver Strain Index (CSI) | Caregivers for symptomatic advanced cancer patients | ND
Cooper, 2006^43^ | Family Appraisal of Caregiving Questionnaire for Palliative Care (FACQ-PC) | Caregivers of palliative care patients | ND
Cohen, 2006^44^ | Quality of Life in Life-Threatening Illness-Family Carer Version (QOLLTI-F) | Caregivers of palliative cancer patients | ND
Higginson, 2010^45^ | Zarit Burden Inventory (ZBI) | Advanced conditions | ND

CBS-EOLC =Caregiver's Burden Scale in end-of-life care; CIS =Caregiver Impact Scale; CQOLI-C =Caregiver Quality of Life Index – Cancer; CRA =Caregiver Reaction Assessment; CSI=Caregiver Strain Index; FACQ-PC =Family Appraisal of Caregiving Questionnaire for Palliative Care; ND=no data available (review did not abstract); QOLLTI-F =Quality of Life in Life-Threatening Illness-Family Carer Version; ZBI =Zarit Burden Inventory

* Note that a CQOLI-R version for hospice patients is also available with data

Evidence Table 4c Domain characteristics of tools included in the selected review, Michels, 2016^37^ addressing the social domain

Author, year, of individual study(s) within the review for each tool | Instrument | Domain (from NCP national guidelines) | Subdomains of NCP domain addressed (eg, pain, dyspnea) | Sub-scales
Dumont, 2008^38^ | CBS-EOLC | Social | ND | ND
Cameron, 2002^39^ | CIS | Social | ND | ND
Weitzner, 1999^40^ | CQOLI-C | Social | ND | ND
Hudson, 2006^41^ | CRA | Social | ND | ND
Hwang, 2003^42^ | CSI | Social | ND | ND
Cooper, 2006^43^ | FACQ-PC | Social | ND | ND
Cohen, 2006^44^ | QOLLTI-F | Social | ND | ND
Higginson, 2010^45^ | ZBI | Social | ND | ND

CBS-EOLC =Caregiver's Burden Scale in end-of-life care; CIS =Caregiver Impact Scale; CQOLI-C =Caregiver Quality of Life Index - Cancer; CRA =Caregiver Reaction Assessment; CSI=Caregiver Strain Index; FACQ-PC =Family Appraisal of Caregiving Questionnaire for Palliative Care; ND=no data available (review did not abstract); QOLLTI-F =Quality of Life in Life-Threatening Illness-Family Carer Version; ZBI =Zarit Burden Inventory

Evidence Table 4d Measurement characteristics of tools included in the selected review, Michels, 2016^37^ addressing the social domain

Author, year, of relevant individual study(s) within the review for each tool | Instrument (abbreviation) | Form completed by | Mode of administration | Number of items | Completion time (usability)
Dumont, 2008^38^ | CBS-EOLC | ND | ND | 16 | N
Cameron, 2002^39^ | CIS | ND | ND | 14 | N
Weitzner, 1999^40^ | CQOLI-C | ND | ND | 35 | 10 minutes
Hudson, 2006^41^ | CRA | ND | ND | 24 | N
Hwang, 2003^42^ | CSI | ND | ND | 13 | N
Cooper, 2006^43^ | FACQ-PC | ND | ND | 26 | N
Cohen, 2006^44^ | QOLLTI-F | ND | ND | 16 | N
Higginson, 2010^45^ | ZBI | ND | ND | 22 | N

CBS-EOLC =Caregiver's Burden Scale in end-of-life care; CIS =Caregiver Impact Scale; CQOLI-C =Caregiver Quality of Life Index – Cancer; CRA =Caregiver Reaction Assessment; CSI=Caregiver Strain Index; FACQ-PC =Family Appraisal of Caregiving Questionnaire for Palliative Care; N=not present in the primary article; ND=no data available (review did not abstract); QOLLTI-F =Quality of Life in Life-Threatening Illness-Family Carer Version; ZBI =Zarit Burden Inventory

Evidence Table 4e Psychometric properties of tools included in the selected review, Michels, 2016^37^ addressing the social domain

Author, year, of individual study(s) within the review for each tool | Instrument abbreviation | Reliability: Internal consistency (Total score if present) | Test-retest reliability | Inter-rater reliability | Convergent validity (Type of construct validity) | Specific construct validity results: discriminant, criterion) | Sensitivity to change/responsiveness
Dumont, 2008^38^ | CBS-EOLC | α=0.95 | N | ND | Y | Y | Y
Cameron, 2002^39^ | CIS | α=0.87 | N | ND | N | N | N
Weitzner, 1999^40^ | CQOLI-C | α=0.91 | Y | ND | Y | Y | Y
Hudson, 2006^41^ | CRA | α=0.76–0.83 | N | ND | Y | N | N
Hwang, 2003^42^ | CSI | α=0.84 | NR | ND | Y | N | N
Cooper, 2006^43^ | FACQ-PC | α=0.73–0.86 | Y | ND | Y | N | N
Cohen, 2006^44^ | QOLLTI-F | α=0.86 | Y | ND | Y | N | Y
Higginson, 2010^45^ | ZBI | α=0.69–0.93 | N | ND | Y | N | N

CBS-EOLC =Caregiver's Burden Scale in end-of-life care; CIS =Caregiver Impact Scale; CQOLI-C =Caregiver Quality of Life Index – Cancer; CRA =Caregiver Reaction Assessment; CSI=Caregiver Strain Index; FACQ-PC =Family Appraisal of Caregiving Questionnaire for Palliative Care ; N=not present in the primary article; ND=no data available (review did not abstract); QOLLTI-F =Quality of Life in Life-Threatening Illness-Family Carer Version; Y=present in the primary article; ZBI =Zarit Burden Inventory

(Note that for this review's, definition of construct validity was not same as we had defined and sometimes factor analysis is reported here; we coded this as Y)

Evidence Table 5a Characteristics of the selected review, Selman, 2011^46^ addressing the spiritual, religious, and existential domain

Author, year | Review focus – NCP domain, tool (and definition if relevant), population, setting | Inclusion criteria | Number of tools in the review and number included (number of studies) | Years of search (range)
Selman, 2011^46^ | Spirituality | Measures related to “palliative care” and “spirituality” and “outcome measure”; original research or validating measures; must be in English. | 9 in review, 2 patient/family assessments included here. | Through June 10, 2010: No restriction on start date of searches

NCP=National Consensus Project for Quality Palliative Care Clinical Practice

Evidence Table 5b Population and setting of tools included in the selected review, Selman, 2011^46^ addressing the spiritual, religious, and existential domain

Author, year, of relevant individual study(s) within the review for each tool | Instrument (s) (Full name and abbreviation) | Population (s)- | Setting where testing results are reported from
Rosenfeld, 2004^47^ Nissim, 2010^48^ Abbey, 2006^49^ | Beck Hopelessness Scale (BHS) | Ethnically diverse U.S. population; made for a general population but has been validated in palliative care population. | Inpatient
Ironson, 2002^50^ | Ironson-Woods Spirituality/Religiousness Index (I-W SR Index Short Form) | Ethnically diverse US population | ND

BHS =Beck Hopelessness Scale; I-W SR Index Short Form =Ironson-Woods Spirituality/Religiousness Index; ND=no data available (review did not abstract)

Evidence Table 5c Domain characteristics of tools included in the selected review, Selman, 2011^46^ addressing the spiritual, religious, and existential domain

Author, year, of relevant individual study(s) within the review for each tool | Instrument | Domain (from NCP national guidelines) | Subdomains of NCP domain addressed (eg, pain, dyspnea) | Sub-scales
Rosenfeld, 2004^47^ Nissim, 2010^48^ Abbey, 2006^49^ | BHS | Spirituality | Hopelessness | ND
Ironson, 2002^50^ | I-W SR Index Short Form | Spirituality | ND | ND

BHS =Beck Hopelessness Scale; I-W SR Index Short Form =Ironson-Woods Spirituality/Religiousness Index; ND=no data available (review did not abstract)

* Was defined in review as the “Spiritual Constructs Measured (as stated in validation article)”

Evidence Table 5d Measurement characteristics of tools included in the selected review, Selman, 2011^46^ addressing the spiritual, religious, and existential domain

Author, year, of relevant individual study(s) within the review for each tool | Instrument (abbreviation) | Form completed by | Mode of administration | Number of items | Completion time (usability)
Rosenfeld, 2004^47^ Nissim, 2010^48^ Abbey, 2006^49^ | BHS | ND | ND | 20 | N
Ironson, 2002^50^ | I-W SR Index Short Form | ND | ND | 22 | N

BHS =Beck Hopelessness Scale; I-W SR Index Short Form =Ironson-Woods Spirituality/Religiousness Index; N=not present in the primary article; ND=no data available (review did not abstract)

Evidence Table 5e Psychometric properties of tools included in the selected review, Selman, 2011^46^ addressing the spiritual, religious, and existential domain

Author, year, of individual study(s) within the review for each tool | Instrument abbreviation | Reliability: Internal consistency (Total score if present) | Test-retest reliability | Inter-rater reliability | Construct validity | Specific construct validity results: discriminant, criterion) | Sensitivity to change/responsiveness
Rosenfeld, 2004^47^ Nissim, 2010^48^ Abbey, 2006^49^ | BHS | Y | N | N | Y | Y | Y
Ironson, 2002^50^ | I-W SR Index Short Form | Y | Y | N | Y | Y | Y

BHS =Beck Hopelessness Scale; I-W SR Index Short Form =Ironson-Woods Spirituality/Religiousness Index; N=not present in the primary article; Y=present in the primary article

Evidence Table 6a Characteristics of the selected review, Sealey, 2015^51^ addressing care of the patient at end of life (bereavement)

Author, year | Review focus – NCP domain, tool (and definition if relevant), population, setting | Inclusion criteria | Number of tools included (number of studies) | Years of search (range)
Sealey, 2015^51^ | End-of-life: bereavement^*^ | Bereavement risk assessment measures appropriate for different points in the caring and bereavement trajectories | 19 in review, 17 patient/family assessments included here | 1980 through August 2014

NCP=National Consensus Project for Quality Palliative Care Clinical Practice

* Scoping review

Evidence Table 6b Population and setting of tools in the selected review, Sealey, 2015^51^ addressing care of the patient at end of life (bereavement)

Author, year, of individual study(s) within the review for each tool | Instrument (s) (Full name and abbreviation) | Population (s) | Setting where testing results are reported from
Guarnaccia, 1998^52^ | Bereavement Experience Questionnaire–24 (BEQ-24) | Bereaved adults | N
Shear, 2006^53^ Ito, 2012^54^ Fujisawa, 2010^55^ | Brief Grief Questionnaire (BGQ) | Recipients of crisis counselling following 911 terrorist attacks; bereaved community dwelling adults | Outpatient
Burnett, 1997^56^ | Core Bereavement Items (CBI) | Bereaved adults | N
Jordan, 2005^57^ | Grief Evaluation Measure (GEM) | Bereaved adults: | N
Barrett, 1989^58^ | Grief Experience Questionnaire (GEQ) | Conjugally bereaved adults to suicide, natural causes or accidental death | N
Hogan, 2001^59^ | Hogan Grief Reaction Checklist (HGRC) | Parentally bereaved people | N
Prigerson, 1995^60^ | Inventory of Complicated Grief (ICG) | Conjugally bereaved elders | N
Prigerson, 2009^61^ O'Connot, 2010^62^ Guldin, 2011^63^ | Inventory of Complicated Grief–Revised (ICG-R) | Conjugally bereaved elders | N
Prigerson, 2001^64^. | Inventory of Traumatic Grief (ITG) | Elderly widowed residents; bereaved adults | N
Marwit, 2002^65^ Marwit, 2006^66^ Marwit, 2008^67^ | Marwit–Meuser Caregiver Grief Inventory (MMCGI) (and short form) | Caregivers of people with dementia, acquired brain injury, cancer | N
Marwit, 2005^68^ | Marwit–Meuser Caregiver Grief Inventory–Short Form (MM-CGI-SF) | Adult caregivers of people with dementia | N
Kiely, 2008^69^ Lai, 2014^70^ | Prolonged Grief–12 (PG-12) | Caregivers of people with dementia, hospice patients | Residential aged care (person who died)
Lichtenthal, 2011^71^ Papa, 2014^72^ | Prolonged Grief–13 (PG-13) | Adults; bereaved caregivers with prolonged grief disorder | N
Lev, 1993^73^ | Revised Grief Experience Inventory (R-GEI) | Hospice caregivers following the death of a loved one | N
Faschingbauer, 1987^74^ Zisook, 1982^75^ Faschingbauer, 1977^76^ Futterman, 2010^77^ | Texas Revised Inventory of Grief (TRIG) | Bereaved psychiatric outpatients; bereaved adults | Outpatient
Rubin, 2009^78^ | Two-Track Bereavement Questionnaire (TTBQ) | Bereaved adults | N
Bar Nadav, 2014^79^ | Two-Track Bereavement Questionnaire (TTBQ2-CG30) | Adults bereaved by traumatic deaths | N

BEQ-24=Bereavement Experience Questionnaire-24; BGQ =Brief Grief Questionnaire; CBI =Core Bereavement Items; GEM =Grief Evaluation Measure; GEQ =Grief Experience Questionnaire; HGRC =Hogan Grief Reaction Checklist; ICG =Inventory of Complicated Grief; ICG-R =Inventory of Complicated Grief-Revised; ITG =Inventory of Traumatic Grief; MMCGI =Marwit–Meuser Caregiver Grief Inventory and short form; MM-CGI-SF =Marwit–Meuser Caregiver Grief Inventory–Short Form; PG-12=Prolonged Grief–12; PG-13=Prolonged Grief–13; N=not present in the primary article; R-GEI =Revised Grief Experience Inventory; TRIG =Texas Revised Inventory of Grief; TTBQ =Two-Track Bereavement Questionnaire; TTBQ2-CG30=Two-Track Bereavement Questionnaire

Evidence Table 6c Domain characteristics of tools in the selected review, Sealey, 2015^51^ addressing care of the patient at end of life (bereavement)

Author, year, of relevant individual study(s) within the review for each tool | Instrument | Domain (from NCP national guidelines) | Subdomains of NCP domain addressed (eg, pain, dyspnea) | Sub-scales
Guarnaccia, 1998^52^ | BEQ-24 | End of life | Bereavement (following a patient's death) | N
Shear, 2006^53^ Ito, 2012^54^ Fujisawa, 2010^55^ | BGQ | End of life | Bereavement (complicated or prolonged bereavement following a patient's death) | N
Burnett, 1997^56^ | CBI | End of life | Bereavement (following a patient's death) | Images and thoughts, acute separation and grief
Jordan, 2005^57^ | GEM | End of life | Bereavement (following a patient's death) | Seven sections
Barrett, 1989^58^ | GEQ | End of life | Bereavement (following a patient's death) | Somatic and general grief reactions, meaning making, social support, stigmatization, guilt, responsibility for the death, shame, rejection, self-destructive behavior and reactions exclusive to suicide survivors
Hogan, 2001^59^ | HGRC | End of life | Bereavement (following a patient's death) | Six factors
Prigerson, 1995^60^ | ICG | End of life | Bereavement (complicated or prolonged bereavement following a patient's death) | N
Prigerson, 2009^61^ O'Connot, 2010^62^ Guldin, 2011^63^ | ICG-R | End of life | Bereavement (complicated or prolonged bereavement following a patient's death) | Two factors
Prigerson, 2001^64^. | ITG | End of life | Bereavement (following a patient's death) | Two factors
Marwit, 2002^65^ Marwit, 2006^66^ Marwit, 2008^67^ | MMCGI | End of life | Bereavement (pre-death risk) | Personal sacrifice burden, heartfelt sadness and longing and worry and felt isolation
Marwit, 2005^68^ | MM-CGI-SF | End of life | Bereavement (pre-death risk) | Personal sacrifice burden, heartfelt sadness and longing and worry and felt isolation
Kiely, 2008^69^ Lai, 2014^70^ | PG-12 | End of life | Bereavement (pre-death risk) | N
Lichtenthal, 2011^71^ Papa, 2014^72^ | PG-13 | End of life | Bereavement (complicated or prolonged bereavement following a patient's death) | N
Lev, 1993^73^ | R-GEI | End of life | Bereavement (following a patient's death) | Existential concerns, depression, feelings of tension and guilt and physical distress
Faschingbauer, 1987^74^ Zisook, 1982^75^ Faschingbauer, 1977^76^ Futterman, 2010^77^ | TRIG | End of life | Bereavement (following a patient's death) | Past behavior and present feelings
Rubin, 2009^78^ | TTBQ | End of life | Bereavement (following a patient's death) | Five factors
Bar Nadav, 2014^79^ | TTBQ2-CG30 | End of life | Bereavement (following a patient's death) | Four factors

BEQ-24=Bereavement Experience Questionnaire-24; BGQ =Brief Grief Questionnaire; CBI =Core Bereavement Items; GEM =Grief Evaluation Measure; GEQ =Grief Experience Questionnaire; HGRC =Hogan Grief Reaction Checklist; ICG =Inventory of Complicated Grief; ICG-R =Inventory of Complicated Grief-Revised; ITG =Inventory of Traumatic Grief; MMCGI =Marwit-Meuser Caregiver Grief Inventory and short form; MM-CGI-SF =Marwit-Meuser Caregiver Grief Inventory-Short Form; PG-12=Prolonged Grief-12; PG-13=Prolonged Grief-13; N=not present in the primary article; R-GEI =Revised Grief Experience Inventory; TRIG =Texas Revised Inventory of Grief; TTBQ =Two-Track Bereavement Questionnaire; TTBQ2-CG30=Two-Track Bereavement Questionnaire

Evidence Table 6d Measurement characteristics of tools in the selected review, Sealey, 2015^51^ addressing care of the patient at end of life (bereavement)

Author, year, of relevant individual study(s) within the review for each tool | Instrument (abbreviation) | Form completed by | Mode of administration | Number of items | Completion time (usability)
Guarnaccia, 1998^52^ | BEQ-24 | Caregiver | ND | 24 | N
Shear, 2006^53^ Ito, 2012^54^ Fujisawa, 2010^55^ | BGQ | Caregiver | ND | 5 | N
Burnett, 1997^56^ | CBI | Caregiver | ND | 17 | N
Jordan, 2005^57^ | GEM | Caregiver | ND | 91 | 30-35 minutes
Barrett, 1989^58^ | GEQ | Caregiver | ND | 55 | < 20 minutes
Hogan, 2001^59^ | HGRC | Caregiver | ND | 61 | N
Prigerson, 1995^60^ | ICG | Caregiver | ND | 19 | N
Prigerson, 2009^61^ O'Connot, 2010^62^ Guldin, 2011^63^ | ICG-R | Caregiver | ND | 15 | N
Prigerson, 2001^64^. | ITG | Caregiver | ND | 34 | N
Marwit, 2002^65^ Marwit, 2006^66^ Marwit, 2008^67^ | MMCGI | Caregiver | ND | 50 | N
Marwit, 2005^68^ | MM-CGI-SF | Caregiver | ND | 18 | N
Kiely, 2008^69^ Lai, 2014^70^ | PG-12 | Caregiver | ND | 12 | N
Lichtenthal, 2011^71^ Papa, 2014^72^ | PG-13 n | Caregiver | ND | 13 | N
Lev, 1993^73^ | R-GEI | Caregiver | ND | 22 | N
Faschingbauer, 1987^74^ Zisook, 1982^75^ Faschingbauer, 1977^76^ Futterman, 2010^77^ | TRIG | Caregiver | ND | 21 | N
Rubin, 2009^78^ | TTBQ | Caregiver | ND | 70 | N
Bar Nadav, 2014^79^ | TTBQ2-CG30 | Caregiver | ND | 30 | ND

BEQ-24=Bereavement Experience Questionnaire–24; BGQ =Brief Grief Questionnaire; CBI =Core Bereavement Items; GEM =Grief Evaluation Measure; GEQ =Grief Experience Questionnaire; HGRC =Hogan Grief Reaction Checklist; ICG =Inventory of Complicated Grief; ICG-R =Inventory of Complicated Grief–Revised; ITG =Inventory of Traumatic Grief; MMCGI =Marwit–Meuser Caregiver Grief Inventory and short form; MM-CGI-SF =Marwit–Meuser Caregiver Grief Inventory–Short Form; PG-12=Prolonged Grief–12; PG-13=Prolonged Grief–13; N=not present in the primary article; ND=no data available (review did not abstract); R-GEI =Revised Grief Experience Inventory; TRIG =Texas Revised Inventory of Grief; TTBQ =Two-Track Bereavement Questionnaire; TTBQ2-CG30=Two-Track Bereavement Questionnaire

Evidence Table 6e Psychometric properties of tools in the selected review, Sealey, 2015^51^ addressing care of the patient at end of life (bereavement)

Author, year, of individual study(s) within the review for each tool | Instrument abbreviation | Reliability: Internal consistency (Total score if present) | Test-retest reliability | Inter-rater reliability | Construct validity | Specific construct validity results: discriminant, criterion) | Sensitivity to change/responsiveness
Guarnaccia, 1998^52^ | BEQ-24 | Cronbach's alpha 0.70 - 0.84 | N | ND | N | ND | N
Shear, 2006^53^ Ito, 2012^54^ Fujisawa, 2010^55^ | BGQ | Cronbach's alpha 0.75- 0.82 | N | ND | N | ND | N
Burnett, 1997^56^ | CBI | Cronbach's alpha 0.91 | N | ND | Y | ND | N
Jordan, 2005^57^ | GEM | Cronbach's alpha 0.91- 0.97 | Y | ND | N | ND | N
Barrett, 1989^58^ | GEQ | Cronbach's alpha 0.97 | N | ND | N | ND | N
Hogan, 2001^59^ | HGRC | Cronbach's alpha 0.90 | Y | ND | N | ND | N
Prigerson, 1995^60^ | ICG | Cronbach's alpha 0.94 | Y | ND | N | ND | N
Prigerson, 2009^61^ O'Connot, 2010^62^ Guldin, 2011^63^ | ICG-R | Cronbach's alpha 0.90 -0.94 | N | ND | N | ND | N
Prigerson, 2001^64^. | ITG | Cronbach's alpha 0.94-0.95 | Y | ND | N | ND | N
Marwit, 2002^65^ Marwit, 2006^66^ Marwit, 2008^67^ | MM-CGI | Cronbach's alpha 0.86-0.96 | N | ND | Y | ND | N
Marwit, 2005^68^ | MM-CGI-SF | Cronbach's alpha 0.80-0.83 | N | ND | Y | ND | N
Kiely, 2008^69^ Lai, 2014^70^ | PG-12 | Cronbach's alpha 0.81 | N | ND | N | ND | N
Lichtenthal, 2011^71^ Papa, 2014^72^ | PG-13 | Cronbach's alpha total 0.82-0.94 | N | ND | N | ND | N
Lev, 1993^73^ | R-GEI | Cronbach's alpha 0.93 | N | ND | N | ND | N
Faschingbauer, 1987^74^ Zisook, 1982^75^ Faschingbauer, 1977^76^ Futterman, 2010^77^ | TRIG | Cronbach's alpha 0.86; | N | ND | N | ND | N
Rubin, 2009^78^ | TTBQ | Cronbach's alpha 0.94 | N | ND | N | ND | N
Bar Nadav, 2014^*,79^ | TTBQ2-CG30 | Cronbach's alpha 0.91 | N | ND | N | ND | ND

BEQ-24=Bereavement Experience Questionnaire–24; BGQ =Brief Grief Questionnaire; CBI =Core Bereavement Items; GEM =Grief Evaluation Measure; GEQ =Grief Experience Questionnaire; HGRC =Hogan Grief Reaction Checklist; ICG =Inventory of Complicated Grief; ICG-R =Inventory of Complicated Grief–Revised; ITG =Inventory of Traumatic Grief; MMCGI =Marwit–Meuser Caregiver Grief Inventory and short form; MM-CGI-SF =Marwit–Meuser Caregiver Grief Inventory–Short Form; PG-12=Prolonged Grief-12; PG-13=Prolonged Grief–13; N=not present in the primary article; ND=no data available (review did not abstract); R-GEI =Revised Grief Experience Inventory; TRIG =Texas Revised Inventory of Grief; TTBQ =Two-Track Bereavement Questionnaire; TTBQ2-CG30=Two-Track Bereavement Questionnaire; Y=present in the primary article

* Reference for Bar Nadav, 2014 is a conference abstract. Unable to retrieve full text article to verify TTBQ2-CG30, after exhausting all resources.

Evidence Table 7a Characteristics of the selected review, Albers, 2010^80^ addressing multidimensional tools (quality of life)

Author, year | Review focus – NCP domain, tool (and definition if relevant), population, setting | Inclusion criteria | Number of tools included (number of studies) | Years of search (range)
Albers, 2010^80^ | Feasibility and clinimetric quality of QOL measurement instruments suitable for use in palliative care | (1) the study should describe the development or validation of a measurement tool; (2) the measurement instrument should measure (at least one domain of) quality of life in a population of patients for whom there are no further curative treatment options; (3) the study should have investigated at least one measurement property of the instrument; (4) the measurement instrument should have been validated in an English or a Dutch population. | 29 (36 studies) | January 1990 to April 2008

NCP=National Consensus Project for Quality Palliative Care Clinical Practice; QOL=Quality of Life

Evidence Table 7b Population and setting of tools included in the selected review, Albers, 2010^80^ addressing multidimensional tools (quality of life)

Author, year, of individual study(s) within the review for each tool | Instrument (s) (Full name and abbreviation) | Population (s) | Setting where testing results are reported from
Guo, 2001^81^ | Brief Hospice Inventory (BHI) | Hospice patients | Hospice
Ewing, 2004^82^ | Cambridge Palliative Audit Schedule (CAMPAS-R) | Palliative care patients | Home care
Kissane, 2004^83^ | Demoralization Scale (DS) | Cancer patients | Inpatients
Kaasa, 1997^84^ Kaasa, 2001^85^ | Edmonton Functional Assessment Tool (EFAT and EFAT-2) | Cancer patients | Palliative care unit
Schwartz, 2004^86^ | Emanuel and Emanuel Medical Directive | Severely ill patients | Inpatients, dialysis clinics, rehabilitation hospitals, long-term facilities
Blazeby, 2003^87^ | European Organization for Research and Treatment of Cancer Quality of Life Questionnaire – Oesophageal cancer module (EORTC QLQ-OESI8) | Esophageal cancer patients | N
Blazeby, 2004^88^ | European Organization for Research and Treatment of Cancer Quality of Life Questionnaire – Gastric cancer module (EORTC QLQ-ST022) | Patients with adenoma carcinoma of the stomach | N
Chang, 2000^89^ | Edmonton Symptom Assessment Scale (ESAS) | Palliative care patients | In- and outpatients
Lyons, 2009^90^ | Functional Assessment of Chronic Illness Therapy-Palliative Subscale (FACIT-Pal) | Patients with life limiting illness | N
Mcmillan, 1998^91^ McMillan, 2008^92^ | Hospice Quality of Life Index (HQLI) | Hospice patients | Hospice home care
Dobratz, 2004^93^ | Life Closure Scale ( LCS) | Terminally ill patients | Hospice
Salmon, 1996^94^ | Life Evaluation Questionnaire (LEQ) | People with incurable cancer | Outpatient, inpatient
Sterkenberg, 1996^95^ | McMaster Quality of Life Scale (MQLS) | Palliative care patients | In and outpatient, and community-based
Cohen, 1997^96^ Cohen, 2000^97^ | McGill Quality of Life Questionnaire (MQOL) | People with life threatening illness | Palliative care inpatient units, outpatient, home care
Lua, 2005^98^ | McGill Quality of Life Questionnaire-Cardiff Short Form (MQOL-CSF) | Terminally ill patients | Hospice center, inpatient
McCanse, 1995 ^99^ | McCanse Readiness for Death Instrument (MRDI) | Terminally ill patients | Hospice
Sherman, 2007^100^ Lobchuk, 2003^101^ | Memorial Symptom Assessment Scale (MSAS) | Cancer patients | N
Chang, 2004^102^ | Condensed Memorial Symptom Assessment Scale (CMSAS) | Cancer patients | In- and outpatients
Hickman, 2001^103^ | Memorial Symptom Assessment Scale-Global Distress Index (MSAS-GDI) | Cancer patients | Inpatients
Byock, 1998^104^ Schwartz, 2005^105^ | Missoula-VITAS Quality of Life Index (MVQOLI-R) | Terminally ill patients | Hospice, dialysis clinics; hospices; long-term care facilities
Rainbird, 2005^106^ | Needs Assessment for Advanced Cancer Patients (NA-ACP) | Advanced cancer patients | N
Vernooij-Dassen, 2005^107^ | Patient Autonomy Questionnaire (PAQ) | Palliative cancer patients | N
Chochinov, 2008^108^ | Patient Dignity Inventory (PDI) | Patients nearing the end of life | Inpatients
Osse, 2004^109^ | Problems and Needs in Palliative Care questionnaire (PNPC) | Palliative care patients | Home
Osse, 2007^110^ | Problems and Needs in Palliative Care questionnaire-short version (PNPC-sv) | Palliative care patients | Home
Hearn, 1999^111^ | Palliative care Outcome Scale (POS) | Advanced cancer patients | Centers providing palliative care, including inpatient, outpatient, day, home and primary care
Steinhauser, 2004^112^ | Quality of life at the end of life (QUAL-E) | Seriously ill patients | N
Hermann, 2006^113^ | Spiritual Needs Inventory (SNI) | Patients near the end of life | Outpatient and inpatient hospice

BHI=Brief Hospice Inventory; CAMPAS-R=Cambridge Palliative Audit Schedule; CMSAS=Condensed Memorial Symptom Assessment Scale; DS=Demoralization Scale; EFAT=Edmonton Functional Assessment Tool ; EFAT-2=Edmonton Functional Assessment Tool; EORTC QLQ-OESI8=European Organization for Research and Treatment of Cancer Quality of Life Questionnaire – Oesophageal cancer module; EORTC QLQ-ST022=European Organization for Research and Treatment of Cancer Quality of Life Questionnaire – Gastric cancer module; ESAS=Edmonton Symptom Assessment Scale; FACIT-Pal=Functional Assessment of Chronic Illness Therapy-Palliative Subscale; HQLI=Hospice Quality of Life Index; LCS=Life Closure Scale; LEQ=Life Evaluation Questionnaire; MQLS=McMaster Quality of Life Scale; MQOL=McGill Quality of Life Questionnaire; MQOL-CSF=McGill Quality of Life Questionnaire-Cardiff Short Form; MRDI=McCanse Readiness for Death Instrument; MSAS=Memorial Symptom Assessment Scale; MSAS-GDI=Memorial Symptom Assessment Scale-Global Distress Index; MVQOLI-R=Missoula-VITAS Quality of Life Index; N=not present in the primary article; NA-ACP=Needs Assessment for Advanced Cancer Patients; N=not present in the primary article; PAQ=Patient Autonomy Questionnaire; PDI=Patient Dignity Inventory; PNPC=Problems and Needs in Palliative Care questionnaire; PNPC-sv=Problems and Needs in Palliative Care questionnaire-short version; POS=Palliative care Outcome Scale; QODD=Quality of Dying and Death questionnaire8; QUAL-E=Quality of life at the end of life; SNI=Spiritual Needs Inventory

Evidence Table 7c Domain and subscale characteristics of tools included in the selected review, Albers, 2010^80^ addressing multidimensional tools (quality of life)

Author, year, of relevant individual study(s) within the review for each tool | Instrument | Domain (from NCP national guidelines) | Subdomains of NCP domain addressed (eg, pain, dyspnea) | Sub-scales
Guo, 2001^81^ | BHI | Physical, Psychological and Psychiatric | ND | N
Ewing, 2004^82^ | CAMPAS-R | Physical, Psychological and Psychiatric | ND | Subscale
Kissane, 2004^83^ | DS | Psychological and Psychiatric | ND | Subscale and total
Kaasa, 1997^84^ Kaasa, 2001^85^ | EFAT | Physical | ND | Total
Schwartz, 2004^86^ | Emanuel and Emanuel Medical Directive | Ethical/legal | ND | N
Blazeby, 2003^87^ | EORTC QLQ-OESI8 | Physical | ND | Subscale
Blazeby, 2004^88^ | EORTC QLQ-ST022 | Physical, Psychological and Psychiatric | ND | Subscale
Chang, 2000^89^ | ESAS | Physical, Psychological and Psychiatric | ND | Total
Lyons, 2009^90^ | FACIT-Pal | Physical, Psychological and Psychiatric, Social, Ethical/Legal | ND | Total
Mcmillan, 1998^91^ McMillan, 2008^92^ | HQLI | Physical, Psychological and Psychiatric, Social, Spiritual | ND | Subscale and total
Dobratz, 2004^93^ | LCS | Psychological and Psychiatric | ND | Subscale and total
Salmon, 1996^94^ | LEQ | Psychological and Psychiatric, Social | ND | Subscale
Sterkenberg, 1996^95^ | MQLS | Physical, Psychological and Psychiatric, Social | ND | N
Cohen, 1997^96^ Cohen, 2000^97^ | MQOL | Physical, Psychological and Psychiatric, Social, Spiritual | ND | Subscale and total
Lua, 2005^98^ | MQOL-CSF | Physical, Psychological and Psychiatric, Spiritual | ND | Subscale and total
McCanse, 1995 ^99^ | MRDI | Physical, Psychological and Psychiatric, Social, Spiritual | ND | Total
Sherman, 2007^100^ Lobchuk, 2003^101^ | MSAS | Physical, Psychological and Psychiatric | ND | Subscale and total
Chang, 2004^102^ | CMSAS | Physical, Psychological and Psychiatric | ND | Subscale and total
Hickman, 2001^103^ | MSAS-GDI | Physical, Psychological and Psychiatric | ND | Total
Byock, 1998^104^ Schwartz, 2005^105^ | MVQOLI-R | Physical, Social, Spiritual | ND | Subscale and total
Rainbird, 2005^106^ | NA-ACP | Structure and Process, Physical, Social, Spiritual | ND | Subscale
Vernooij-Dassen, 2005^107^ | PAQ | Ethical/legal | ND | Total
Chochinov, 2008^108^ | PDI | Physical, Social, Spiritual | ND | N
Osse, 2004^109^ | PNPC | Structure and Process, Physical, Psychological and Psychiatric, Social Spiritual, Ethical/Legal | ND | Subscale
Osse, 2007^110^ | PNPC-sv | Structure and Process, Physical, Psychological and Psychiatric, Social Spiritual, Ethical/Legal | ND | Subscale
Hearn, 1999^111^ | POS | Physical, Psychological and Psychiatric, Spiritual | ND | N
Steinhauser, 2004^112^ | QUAL-E | Structure and Process, Psychological and Psychiatric, Ethical/Legal, End of Life | ND | Subscale and total
Hermann, 2006^113^ | SNI | Spiritual | ND | Subscale and total

BHI=Brief Hospice Inventory; CAMPAS-R=Cambridge Palliative Audit Schedule; CMSAS=Condensed Memorial Symptom Assessment Scale; DS=Demoralization Scale; EFAT=Edmonton Functional Assessment Tool ; EFAT-2=Edmonton Functional Assessment Tool; EORTC QLQ-OESI8=European Organization for Research and Treatment of Cancer Quality of Life Questionnaire – Oesophageal cancer module; EORTC QLQ-ST022=European Organization for Research and Treatment of Cancer Quality of Life Questionnaire – Gastric cancer module; ESAS=Edmonton Symptom Assessment Scale; FACIT-Pal=Functional Assessment of Chronic Illness Therapy-Palliative Subscale; HQLI=Hospice Quality of Life Index; LCS=Life Closure Scale; LEQ=Life Evaluation Questionnaire; MQLS=McMaster Quality of Life Scale; MQOL=McGill Quality of Life Questionnaire; MQOL-CSF=McGill Quality of Life Questionnaire-Cardiff Short Form; MRDI=McCanse Readiness for Death Instrument; MSAS=Memorial Symptom Assessment Scale; MSAS-GDI=Memorial Symptom Assessment Scale-Global Distress Index; MVQOLI-R=Missoula-VITAS Quality of Life Index; NA-ACP=Needs Assessment for Advanced Cancer Patients; N=not present in the primary article; ND=no data available (review did not abstract); PAQ=Patient Autonomy Questionnaire; PDI=Patient Dignity Inventory; PNPC=Problems and Needs in Palliative Care questionnaire; PNPC-sv=Problems and Needs in Palliative Care questionnaire-short version; POS=Palliative care Outcome Scale; QODD=Quality of Dying and Death questionnaire8; QUAL-E=Quality of life at the end of life; SNI=Spiritual Needs Inventory

Evidence Table 7d Measurement characteristics of tools included in the selected review, Albers, 2010^80^ addressing multidimensional tools (quality of life)

Author, year, of relevant individual study(s) within the review for each tool | Instrument (abbreviation) | Form completed by | Mode of administration | Number of items | Completion time (usability)
Guo, 2001^81^ | BHI | Patient | N | 17 | 9 minutes
Ewing, 2004^82^ | CAMPAS-R | Patient | N | 2×10 | N
Kissane, 2004^83^ | DS | Patient | N | 24 | N
Kaasa, 1997^84^ Kaasa, 2001^85^ | EFAT | Proxy | N | 11 | N
Schwartz, 2004^86^ | Emanuel and Emanuel Medical Directive | Patient | interview | 48 | 2-3 hours
Blazeby, 2003^87^ | EORTC QLQ-OESI8 | Patient | N | 18 | 15 minutes (including completion of EORTC QLQ-C30)
Blazeby, 2004^88^ | EORTC QLQ-ST022 | Patient | N | 22 | 15 min. (including completion of EORTC QLQ-C30)
Chang, 2000^89^ | ESAS | Patient | N | 10 | 5 minutes
Lyons, 2009^90^ | FACIT-Pal | Patient | N | 19 | N
Mcmillan, 1998^91^ McMillan, 2008^92^ | HQLI | Patient | N | 28 | 10-15 minutes
Dobratz, 2004^93^ | LCS | Patient | N | 20 | N
Salmon, 1996^94^ | LEQ | Patient | N | 44 | N
Sterkenberg, 1996^95^ | MQLS | Patient | N | 32 | 3-30 minutes
Cohen, 1997^96^ Cohen, 2000^97^ | MQOL | Patient | N | 16 | 10-30 minutes
Lua, 2005^98^ | MQOL-CSF | Patient | N | 8 | 3.26 minutes
McCanse, 1995 ^99^ | MRDI | Patient | interview | 28 | N
Sherman, 2007^100^ Lobchuk, 2003^101^ | MSAS | Patient/proxy | N | 32 | 20-60 minutes
Chang, 2004^102^ | CMSAS | Patient | N | 14 | 2-4 minutes
Hickman, 2001^103^ | MSAS-GDI | Proxy | N | 11 | N
Byock, 1998^104^ Schwartz, 2005^105^ | MVQOLI-R | Patient | N | 25 | N
Rainbird, 2005^106^ | NA-ACP | Patient | N | 132 | 76 minutes
Vernooij-Dassen, 2005^107^ | PAQ | Patient | N | 4/9 | N
Chochinov, 2008^108^ | PDI | Patient | N | 25 | 2 minutes (max: 10-15)
Osse, 2004^109^ | PNPC | Patient | N | 138 | N
Osse, 2007^110^ | PNPC-sv | Patient | N | 33 | N
Hearn, 1999^111^ | POS | Patient/proxy | N | 10 | 6.9 minutes
Steinhauser, 2004^112^ | QUAL-E | Patient | interview | 26 | N
Hermann, 2006^113^ | SNI | Patient | N | 17 | N

BHI=Brief Hospice Inventory; CAMPAS-R=Cambridge Palliative Audit Schedule; CMSAS=Condensed Memorial Symptom Assessment Scale; DS=Demoralization Scale; EFAT=Edmonton Functional Assessment Tool ; EFAT-2=Edmonton Functional Assessment Tool; EORTC QLQ-OESI8=European Organization for Research and Treatment of Cancer Quality of Life Questionnaire – Oesophageal cancer module; EORTC QLQ-ST022=European Organization for Research and Treatment of Cancer Quality of Life Questionnaire – Gastric cancer module; ESAS=Edmonton Symptom Assessment Scale; FACIT-Pal=Functional Assessment of Chronic Illness Therapy-Palliative Subscale; HQLI=Hospice Quality of Life Index; LCS=Life Closure Scale; LEQ=Life Evaluation Questionnaire; MQLS=McMaster Quality of Life Scale; MQOL=McGill Quality of Life Questionnaire; MQOL-CSF=McGill Quality of Life Questionnaire-Cardiff Short Form; MRDI=McCanse Readiness for Death Instrument; MSAS=Memorial Symptom Assessment Scale; MSAS-GDI=Memorial Symptom Assessment Scale-Global Distress Index; MVQOLI-R=Missoula-VITAS Quality of Life Index; NA-ACP=Needs Assessment for Advanced Cancer Patients; N=not present in the primary article; ND=no data available (review did not abstract); PAQ=Patient Autonomy Questionnaire; PDI=Patient Dignity Inventory; PNPC=Problems and Needs in Palliative Care questionnaire; PNPC-sv=Problems and Needs in Palliative Care questionnaire-short version; POS=Palliative care Outcome Scale; QODD=Quality of Dying and Death questionnaire8; QUAL-E=Quality of life at the end of life; SNI=Spiritual Needs Inventory

Evidence Table 7e Psychometric properties of tools included in the selected review, Albers, 2010^80^ addressing multidimensional tools (quality of life)

Author, year, of individual study(s) within the review for each tool | Instrument abbreviation | Reliability: Internal consistency (Total score if present) | Test-retest reliability | Inter-rater reliability | Construct validity | Specific construct validity results: discriminant, criterion) | Sensitivity to change/responsiveness
Guo, 2001^81^ | BHI | Cronbach's α of the 2 subscales: 0.88; 0.94 | Y | ND | N | ND | N
Ewing, 2004^82^ | CAMPAS-R | Cronbach's α severity: 0.77; Cronbach's α interference: 0.80 | N | ND | Y | ND | Y
Kissane, 2004^83^ | DS | Cronbach's α: 0.70–0.89 | N | ND | Y | ND | N
Kaasa, 1997^84^ Kaasa, 2001^85^ | EFAT EFAT-2 | EFAT-2 Cronbach's α: 0.86 | N | ND | Y | ND | N
Schwartz, 2004^86^ | Emanuel and Emanuel Medical Directive | Cronbach's α across treatments by scenario: 0.80–0.85; Cronbach's α across scenarios by treatment: 0.86–0.90 | Y | ND | Y | ND | Y
Blazeby, 2003^87^ | EORTC QLQ-OESI8 | Cronbach's α: 0.61–0.75 | N | ND | Y | ND | Y
Blazeby, 2004^88^ | EORTC QLQ-ST022 | Cronbach's α: 0.72–0.80 | N | ND | Y | ND | Y
Chang, 2000^89^ | ESAS | Cronbach's α of the overall ESAS: 0.79 | Y | ND | Y | ND | N
Lyons, 2009^90^ | FACIT-Pal | Cronbach's α: 0.75–0.85 | N | ND | Y | ND | N
Mcmillan, 1998^91^ McMillan, 2008^92^ | HQLI | Cronbach's α: 0.78–0.85 | N | ND | Y | ND | N
Dobratz, 2004^93^ | LCS | Cronbach's α for 2 subscales: 0.80; 0.82 | N | ND | Y | ND | N
Salmon, 1996^94^ | LEQ | Cronbach's α: 0.70–0.85 | Y | ND | Y | ND | N
Sterkenberg, 1996^95^ | MQLS | Cronbach's α for patients: overall scale: 0.8; Cronbach's α for family: overall scale: 0.87 | Y | ND | Y | ND | Y
Cohen, 1997^96^ Cohen, 2000^97^ | MQOL | Cronbach's α: >0.70 except physical subscale (0.62) | Y | ND | Y | ND | Y
Lua, 2005^98^ | MQOL-CSF | Cronbach's α: 0.64–0.81, except existential domain (0.46) | Y | ND | Y | ND | N
McCanse, 1995 ^99^ | MRDI | Cronbach's α of the overall MRDI: 0.59 | Y | ND | Y | ND | N
Sherman, 2007^100^ Lobchuk, 2003^101^ | MSAS, MSAS (FC) | Cronbach's α AIDS patients; caregivers: 0.78–0.87; 0.86–0.91 Cronbach's α cancer patients; caregivers: 0.78–0.83; 0.81–0.86 | N | ND | Y | ND | N
Chang, 2004^102^ | CMSAS | Cronbach's α: 0.72–0.85 | N | ND | Y | ND | N
Hickman, 2001^103^ | MSAS-GDI | Cronbach's α of the overall MSAS-GDI: 0.82 | N | ND | N | ND | N
Byock, 1998^104^ Schwartz, 2005^105^ | MVQOLI, MVQOLI-R | Cronbach's α of the overall MVQOLI: 0.77 | N | ND | Y | ND | Y
Rainbird, 2005^106^ | NA-ACP | Cronbach's α: 0.79–0.98 | Y | ND | N | ND | N
Vernooij-Dassen, 2005^107^ | PAQ | Cronbach's α of the 9-item version: 0.86 Cronbach's α of the 4-item version: 0.71 | N | ND | Y | ND | N
Vernooij-Dassen, 2005^107^ | PDI | Cronbach's α: 0.63–0.83 | Y | ND | Y | ND | N
Chochinov, 2008^108^ | PNPC | Cronbach's α: 0.67–0.89 (problem aspect) | N | ND | Y | ND | N
Osse, 2007^110^ | PNPpC-sv | Cronbach's α: 0.61–0.86 (problem aspect | N | ND | Y | ND | N
Hearn, 1999^111^ | POS | Cronbach's α patient version: 0.65 | Y | ND | Y | ND | Y
Steinhauser, 2004^112^ | QUAL-E | Cronbach's α: 0.68–0.87 | Y | ND | Y | ND | N
Hermann, 2006^113^ | SNI | Cronbach's α: 0.62–0.78 | N | ND | N | ND | N

BHI=Brief Hospice Inventory; CAMPAS-R=Cambridge Palliative Audit Schedule; CMSAS=Condensed Memorial Symptom Assessment Scale; DS=Demoralization Scale; EFAT=Edmonton Functional Assessment Tool; EFAT-2=Edmonton Functional Assessment Tool; EORTC QLQ-OESI8=European Organization for Research and Treatment of Cancer Quality of Life Questionnaire – Oesophageal cancer module; EORTC QLQ-ST022=European Organization for Research and Treatment of Cancer Quality of Life Questionnaire – Gastric cancer module; ESAS=Edmonton Symptom Assessment Scale; FACIT-Pal=Functional Assessment of Chronic Illness Therapy-Palliative Subscale; HQLI=Hospice Quality of Life Index; LCS=Life Closure Scale; LEQ=Life Evaluation Questionnaire; MQLS=McMaster Quality of Life Scale; MQOL=McGill Quality of Life Questionnaire; MQOL-CSF=McGill Quality of Life Questionnaire-Cardiff Short Form; MRDI=McCanse Readiness for Death Instrument; MSAS=Memorial Symptom Assessment Scale; MSAS-GDI=Memorial Symptom Assessment Scale-Global Distress Index; MVQOLI-R=Missoula-VITAS Quality of Life Index; NA-ACP=Needs Assessment for Advanced Cancer Patients; N=not present in the primary article; ND=no data available (review did not abstract); PAQ=Patient Autonomy Questionnaire; PDI=Patient Dignity Inventory; PNPC=Problems and Needs in Palliative Care questionnaire; PNPC-sv=Problems and Needs in Palliative Care questionnaire-short version; POS=Palliative care Outcome Scale; QODD=Quality of Dying and Death questionnaire8; QUAL-E=Quality of life at the end of life; SNI=Spiritual Needs Inventory; Y=present in the primary article

Evidence Table 8a Characteristics of the selected review, Lendon, 2015^114^ addressing multidimensional tools (patient experience)

Author, year | Review focus – NCP domain, tool (and definition if relevant), population, setting | Inclusion criteria | Number of tools in the review and number included (number of studies) | Years of search (range)
Lendon, 2015^114^ | Multiple domains, Surveys on End of life care, End-of-life care settings | Measured areas of patient, Family member, or informal caregiver satisfaction And experience with end-of-life care and Included survey questions or instruments regarding Patient/caregiver satisfaction or experience with End-of-life care | Out of 51 tools, included 8 US tools with detailed abstraction in the review (31 articles) | 1990 to 2012

NCP=National Consensus Project for Quality Palliative Care Clinical Practice

Evidence Table 8b Population and setting of tools included in the selected review, Lendon, 2015^114^ addressing multidimensional tools (patient experience)

Author, year, of individual study(s) within the review for each tool | Instrument (s) (Full name and abbreviation) | Population (s) | Setting where testing results are reported from
Arcand et al, 2009^115^ Baker et al, 2000^116^ Bakitas et al, 2008^117^ Cohen et al, 2012^118^ Gelfman et al, 2008^119^ Hallenbeck et al, 2007^120^ Shega et al, 2008^121^ Teno et al, 2001^122^ | After Death Bereaved Family Member Interview | Close relatives; Surrogates: Caregivers | Nursing home; Hospitals; Medical centers; geriatric clinic; Inpatient and outpatient hospice
Kiely, 2006^123^ Cohen et al, 2012^118^ van der Steen et al, 2009^124^ | End of Life in Dementia-Satisfaction with Care & Comfort Assessment in Dying | Residents or health care proxies (if resident died before followup); Caregivers | Nursing homes
Alici, 2010 ^125^ Casarett, 2010^126^ Finlay, 2008^127^ Lu et al, 2010^128^ Smith et al, 2011^129^ | Family Assessment of Treatment of End-of-Life survey | Family members | Veterans Administration medical center
Connot et al, 2005^130^ Mitchell et al, 2007^131^ Rhodes et al, 2008^132^ Rhodes et al, 2007^133^ Schockett et al, 2005^134^ Teno et al, 2004^135^ Teno et al, 2007^136^ York et al, 2009^137^ | Family Evaluation of Hospice Care | Family members | Hospice, home, hospitals, long-term care
Curtis et al, 2008^138^ Gries et al, 2008^139^ Lewis-Newby et al, 2011^140^ | Family Satisfaction in the ICU | Family members | Intensive care unit; Medical Center
Aoun, 2010^141^ Carter, 2011^142^ Lo, 2009^143^ Lo, 2009^144^ Ringdal, 2003 ^145^ Follwell et al, 2009^146^ Kristjanson et al, 1997^147^ Meyers and Gray, 2001^148^ | Family Satisfaction with Advanced Cancer Care (FAMCARE) | Caregivers; Family members | Inpatient and home-based palliative services Oncology outpatient clinic Hospital Home care
Mularski, 2004^149^ Hales et al, 2012^150^ Johnson et al, 2006^151^ Lewis-Newby et al, 2011^140^ Mularski et al, 2005^152^ Notris et al, 2007^153^ | Quality of Dying and Death | Family members | Medical center, cancer center, intensive care unit
Astrow et al, 2007^154^ Sulmasy et al, 2002a^155^ Sulmasy et al, 2002b^156^ | Quality of End-of-Life Care and Satisfaction with Treatment | Patients; family members | Hospitals, cancer center

FAMCARE=Family Satisfaction with Advanced Cancer Care; ICU=intensive care unit

Evidence Table 8c Domain and subscale characteristics of tools included in the selected review, Lendon, 2015^114^ addressing multidimensional tools (patient experience)

Author, year, of relevant individual study(s) within the review for each tool | Instrument | Domain (from NCP national guidelines) | Subdomains of NCP domain addressed (e.g., pain, dyspnea) | Sub-scales
Arcand et al, 2009^115^ Baker et al, 2000^116^ Bakitas et al, 2008^117^ Cohen et al, 2012^118^ Gelfman et al, 2008^119^ Hallenbeck et al, 2007^120^ Shega et al, 2008^121^ Teno et al, 2001^122^ | After Death Bereaved Family Member Interview | Structure and Process; Physical; Spiritual; Psychosocial; Social; End of Life | ND | ND
Kiely, 2006^123^ Cohen et al, 2012^118^ van der Steen et al, 2009^124^ | End of Life in Dementia-Satisfaction with Care & Comfort Assessment in Dying | Structure and Process; Physical; Spiritual; Psychosocial | ND | ND
Alici, 2010 ^125^ Casarett, 2010^126^ Finlay, 2008^127^ Lu et al, 2010^128^ Smith et al, 2011^129^ | Family Assessment of Treatment of End-of-Life survey | Structure and Process; Physical; Social; Psychosocial; Spiritual; End of Life | ND | ND
Connot et al, 2005^130^ Mitchell et al, 2007^131^ Rhodes et al, 2008^132^ Rhodes et al, 2007^133^ Schockett et al, 2005^134^ Teno et al, 2004^135^ Teno et al, 2007^136^ York et al, 2009^137^ | Family Evaluation of Hospice Care | Structure and Process; Physical; Spiritual; Psychosocial; Social; End of Life | ND | ND
Curtis et al, 2008^138^ Gries et al, 2008^139^ Lewis-Newby et al, 2011^140^ | Family Satisfaction in the ICU | Structure and Process; Physical; Spiritual; Social; End of Life | ND | ND
Aoun, 2010^141^ Carter, 2011^142^ Lo, 2009^143^ Lo, 2009^144^ Ringdal, 2003 ^145^ Follwell et al, 2009^146^ Kristjanson et al, 1997^147^ Meyers and Gray,2001^148^ | Family Satisfaction with Advanced Cancer Care | Psychosocial; Physical; Social | ND | ND
Mularski, 2004^149^ Hales et al, 2012^150^ Johnson et al, 2006^151^ Lewis-Newby et al, 2011^140^ Mularski et al, 2005^152^ Notris et al, 2007^153^ | Quality of Dying and Death | Physical; Psychosocial; Spiritual; End of Life | ND | ND
Astrow et al, 2007^154^ Sulmasy et al, 2002a^155^ Sulmasy et al, 2002b^156^ | Quality of End-of-Life Care and Satisfaction with Treatment | Structures and Processes; Spiritual; Psychosocial; | ND | ND

FAMCARE=Family Satisfaction with Advanced Cancer Care; ICU=intensive care unit; ND=no data available (review did not abstract)

Evidence Table 8d Measurement characteristics of tools included in the selected review, Lendon, 2015^114^ addressing multidimensional tools (patient experience)

Author, year, of relevant individual study(s) within the review for each tool | Instrument (abbreviation) | Form completed by | Mode of administration | Number of items | Completion time (usability)
Arcand et al, 2009^115^ Baker et al, 2000^116^ Bakitas et al, 2008^117^ Cohen et al, 2012^118^ Gelfman et al, 2008^119^ Hallenbeck et al, 2007^120^ Shega et al, 2008^121^ Teno et al, 2001^122^ | After Death Bereaved Family Member Interview | Family | Interview | 74 | ND
Kiely, 2006^123^ Cohen et al, 2012^118^ van der Steen et al, 2009^124^ | End of Life in Dementia-Satisfaction with Care & Comfort Assessment in Dying | Patients; Family | Interview; Paper | 41 | ND
Alici, 2010 ^125^ Casarett, 2010^126^ Finlay, 2008^127^ Lu et al, 2010^128^ Smith et al, 2011^129^ | Family Assessment of Treatment of End-of-Life survey | Family | Paper; Interview | 58 | ND
Connot et al, 2005^130^ Mitchell et al, 2007^131^ Rhodes et al, 2008^132^ Rhodes et al, 2007^133^ Schockett et al, 2005^134^ Teno et al, 2004^135^ Teno et al, 2007^136^ York et al, 2009^137^ | Family Evaluation of Hospice Care | Family | Paper; Interview | 56 | ND
Curtis et al, 2008^138^ Gries et al, 2008^139^ Lewis-Newby et al, 2011^140^ | Family Satisfaction in the ICU | Family | Paper; Interview | 25 | ND
Aoun, 2010^141^ Carter, 2011^142^ Lo, 2009^143^ Lo, 2009^144^ Ringdal, 2003 ^145^ Follwell et al, 2009^146^ Kristjanson et al, 1997^147^ Meyers and Gray, 2001^148^ | Family Satisfaction with Advanced Cancer Care | Family | Paper; Interview; Computer | 30 | ND
Mularski, 2004^149^ Hales et al, 2012^150^ Johnson et al, 2006^151^ Lewis-Newby et al, 2011^140^ Mularski et al, 2005^152^ Notris et al, 2007^153^ | Quality of Dying and Death | Family | Paper; Interview | 48 | ND
Astrow et al, 2007^154^ Sulmasy et al, 2002a^155^ Sulmasy et al, 2002b^156^ | Quality of End-of-Life Care and Satisfaction with Treatment | Patients; Family | Interview | 47 | ND

FAMCARE=Family Satisfaction with Advanced Cancer Care; ICU=intensive care unit; ND=no data available (review did not abstract)

Evidence Table 8e Psychometric properties of tools included in the selected review, Lendon, 2015^114^ addressing multidimensional tools (patient experience)

Author, year, of individual study(s) within the review for each tool | Instrument abbreviation | Reliability: Internal consistency (Total score if present) | Test-retest reliability | Inter-rater reliability | Construct validity | Specific construct validity results: discriminant, criterion) | Sensitivity to change/responsiveness
Arcand et al, 2009^115^ Baker et al, 2000^116^ Bakitas et al, 2008^117^ Cohen et al, 2012^118^ Gelfman et al, 2008^119^ Hallenbeck et al, 2007^120^ Shega et al, 2008^121^ Teno et al, 2001^122^ | After Death Bereaved Family Member Interview | Cronbach's α: 0.71-0.80 | Y | Y | Y | Y | N
Kiely, 2006^123^ Cohen et al, 2012^118^ van der Steen et al, 2009^124^ | End of Life in Dementia-Satisfaction with Care & Comfort Assessment in Dying | Cronbach's α: 0.83 | N | N | N | N | N
Alici, 2010 ^125^ Casarett, 2010^126^ Finlay, 2008^127^ Lu et al, 2010^128^ Smith et al, 2011^129^ | Family Assessment of Treatment of End-of-Life survey | Cronbach's α:0.84 | N | N | N | Y | N
Connot et al, 2005^130^ Mitchell et al, 2007^131^ Rhodes et al, 2008^132^ Rhodes et al, 2007^133^ Schockett et al, 2005^134^ Teno et al, 2004^135^ Teno et al, 2007^136^ York et al, 2009^137^ | Family Evaluation of Hospice Care | N | N | N | N | N | N
Curtis et al, 2008^138^ Gries et al, 2008^139^ Lewis-Newby et al, 2011^140^ | Family Satisfaction in the ICU | Cronbach's α: 0.86 | ND | Y | Y | N | N
Aoun, 2010^141^ Carter, 2011^142^ Lo, 2009^143^ Lo, 2009^144^ Ringdal, 2003 ^145^ Follwell et al, 2009^146^ Kristjanson et al, 1997^147^ Meyers and Gray, 2001^148^ | Family Satisfaction with Advanced Cancer Care | N | N | N | N | N | N
Mularski, 2004^149^ Hales et al, 2012^150^ Johnson et al, 2006^151^ Lewis-Newby et al, 2011^140^ Mularski et al, 2005^152^ Notris et al, 2007^153^ | Quality of Dying and Death | Y | N | N | Y | Y | N
Astrow et al, 2007^154^ Sulmasy et al, 2002a^155^ Sulmasy et al, 2002b^156^ | Quality of End-of-Life Care and Satisfaction with Treatment | Cronbach's α: 0.83 – 0.95 | Y | Y | Y | Y | N

FAMCARE=Family Satisfaction with Advanced Cancer Care; ICU=intensive care unit; ND=no data available (review did not abstract)

ND=no data available (review did not abstract)

Evidence Table 9a Characteristics of the selected review, Antunes, 2014^157^ addressing tools used in clinical care

Author, year | Review focus – NCP domain, tool (and definition if relevant), population, setting | Inclusion criteria | Number of tools in the review and number included (number of studies) | Years of search (range)
Antunes, 2014^157^ | Any patient-reported outcome measure in palliative care | Studies using a patient-reported outcome measure (PROM) alongside the clinical care of adult patients with advanced disease in palliative care settings; and reporting barriers and/or facilitators of the implementation of the PROM | 26 in 31 articles; only US studies (7 of the total) and reporting actual tools were abstracted | 1985 to 2011

NCP=National Consensus Project for Quality Palliative Care Clinical Practice

Evidence Table 9b Instruments used in the selected review, Antunes, 2014^157^ addressing tools used in clinical care

Author, year | Sample | Physical | Psychological | Social | Spiritual | Cultural | Care of the Patient at the End of Life | Ethical and Legal | Cross domains (experience) | Cross domains (QOL)
Schulman-Green, 2010^158^ | hospices | N | N | N | N | N | N | N | N | ESAS
Schwartz, 2005^105^ | Hospice, home and palliative care settings | N | N | N | N | N | N | N | N | MVQOLI-R, MSAS
Escalante, 2008^159^ | Emergency center, cancer | NRS for fatigue and pain | N | N | N | N | N | N | N | N
Kamel, 2001^160^ | Nursing homes | VAS for pain | N | N | N | N | N | N | N | N
Chang,2002^161^ | Oncology clinic | N | N | N | N | N | N | N | N | FACT-L
Clark, 2009^162^ | Cancer center | N | ‘How can we help you and your family’ screening instrument | N | N | N | N | N | N | N

ESAS=Edmonton Symptom Assessment Scale; FACT-L= Functional Assessment of Cancer Therapy-Lung; MSAS=Memorial Symptom Assessment Scale; MVQOLI-R=Missoula-VITAS Quality of Life Index; N=not present in the primary article; NRS= Numeric rating scale; VAS=Visual Analogue Scale

Evidence table 10a Characteristics of the selected review, De Roo, 2013^163^ addressing tools used as quality indicators

Author, year | Review focus – NCP domain, tool (and definition if relevant), population, setting | Inclusion criteria | Number of tools in the review and number included (number of studies) | Years of search (range)
De Roo, 2013^163^ | Any quality indicator in palliative care | Describes the development process and/or characteristics of quality indicators developed specifically for palliative care pro- vided by care organizations or professionals. Numerators and denominators are defined for the quality indicators, or the numerators and denominators can be deduced directly from the descriptions of the quality indicators, or performance standards are given. | 17 indicator sets included; 1 in the US included here | Database inception - October 2011

NCP=National Consensus Project for Quality Palliative Care Clinical Practice

Evidence table 10b Instruments used the selected review, De Roo, 2013^163^ addressing tools used as quality indicators

Author, Year | Sample | Structure/Process | Physical | Psychological | Social | Spiritual | Cultural | Care of the Patient at the End of Life | Ethical and Legal | Cross domains (experience) | Cross domains (QOL)
National Quality Forum, 2006^164^ | Hospice | ND | ND | ND | ND | ND | ND | ND | ND | Family evaluation of hospice care | ND

ND=no data available (review did not abstract)

Evidence table 11 Tools used in included articles for Kavalieratos, 2016^165^ evaluating interventions

Author (Year) | Population | Physical Aspects of Care | Psychosocial and Psychiatric Aspects of Care | Cross Domains: Patient Experience | Cross domains: Quality of Life
Ahronheim, 2000^166^ | dementia | NM | NM | NM | NM
Aiken, 2006^167^ | mixed | NM | NM | NM | MSAS
Bakitas, 2009^168^ | cancer | NM | CES-D^*,†^ | NM | ESAS FACIT-Pal
Bakitas, 2015^169^ | cancer | | CES-D^*,†^ | NM | QUAL-E FACIT-Pal FACT TOI^*^
Bekelman, 2015^170^ | CHF | NM | PHQ-9^*,†^ | NM | KCCQ^*^
Brannstrom, 2014^171^ | CHF | NM | NM | NM | ESAS EQ-5D^*^ KCCQ^*^
Brumley, 2007^172^ | mixed | NM | NM | Reid-Gundlach^*^ | NM
Chapman, 2007^173^ | dementia | Faces Legs Activity Cry Consolability Behavioral Pain Scale (FLACC)^*^ Pain in Advanced Dementia (PAINAD)^*^ | Cornell Scale for Depression in Dementia (CSDD)^*,†^ | NM | NM
Cheung, 2010^174^ | ICU inpatients | NM | NM | NM | NM
Clark, 2013^175^ | cancer | NM | POMS^*,†^ | NM | FACT-G^*^
SUPPORT, 1995^176^ | mixed | Scale not reported | NM | NM | NM
Dyar, 2012^177^ | cancer | NM | NM | NM | FACT-G^*^ LASA^*^
Edmonds, 2010^178^ | MS | MS Palliative Outcome Scale-S5^*^ | NM | NM | NM
Engelhardt, 2006^179^ | mixed | NM | NM | NM | NM
Farquhar, 2014^180^ | cancer | NRS^†^ | HADS | NM | NM
Farquhar, 2016^181^ | non-malignant disease and breathlessness | NRS^†^ | HADS | NM | NM
Gade, 2008^182^ | mixed | NM | NM | NM | Modified City of Hope Patient Questionnaire (MCOHPQ)^*^
Given, 2002^183^ | cancer | Symptom Experience Scale^*^ | NM | NM | SF-36^*^
Grande, 1999 & 2000^184, 185^ | mixed | NM | NM | NM | NM
Grudzen, 2016^186^ | cancer | NM | PHQ-9^*,†^ | NM | FACT-G^*^
Hanks, 2002^187^ | cancer | VAS^†^ MPAC^†^ | WONCA^*^ | MacAdam's Assessment of Suffering^*^ | EORTC QLQ-C30
Higginson, 2014^188^ | mixed | NRS^†^ Chronic Respiratory Disease Questionnaire | HADS | NM | EQ-5D^*^
Hopp, 2016^189^ | heart failure | NM | NM | NM | NM
Hughes, 1992^190^ | mixed | NM | NM | Greer Satisfaction with Care Survey^*^ | NM
Jordhoy, 2000 & 2001^191, 192^ | cancer | NM | Impact of Event Scale^*^ | NM | EORTC QLQ-C30
Kane, 1984 & 1985^193, 194^ | cancer | California Pain Assessment Profile^*^ | CES-D^*,†^ General Wellbeing Measure^*^ | Ware Scale^*^ | NM
Lowther, 2015^195^ | HIV | African Palliative Outcomes Scale^*^ | GHQ-12 | NM | MOS-HIV^*^
McCorkle, 1989^196^ | cancer | Symptom Distress Scale^*^ | POMS^*,†^ | NM | NM
McCorkle, 2015^197^ | cancer | Symptom Distress Scale^*^ | HADS PHQ-9^*,†^ | NM | FACT-G^*^
Notthouse, 2005^198^ | cancer | NM | NM | NM | FACT-B^*^ SF-36^*^
Notthouse, 2007^199^ | cancer | Omega Screening Questionnaire^*^ Expanded Prostate Cancer Index Composite^*^ | NM | NM | FACIT-Pal SF-12^*^
Notthouse, 2013^200^ | cancer | NM | NM | NM | FACT-G^*^
Pantilat, 2010^201^ | mixed | NRS^†^ | NRS^†^ | NM | NM
Rabow, 2004^202^ | mixed | UCSD Shortness of Breath Questionnaire Brief Pain Inventory^†^ MOS^*,†^ | POMS^*,†^ CES-D^*,†^ | Group Health Association of America Consumer Satisfaction Survey^*^ | Multidimensional Quality of Life Scale-Cancer^*^
Radwany, 2014^203^ | mixed | NM | HADS | NM | MSAS QUAL-E
Rummans, 2006^204^ | cancer | LASA^*^ Symptom Distress Scale^*^ | POMS^*,†^ | NM | Spitzer Uniscale^*^
Sidebottom, 2015^205^ | CHF | NM | PHQ-9^*,†^ | NM | ESAS Minnesota Living with Heart Failure Questionnaire^*^
Steel, 2016^206^ | cancer | BPI | CES-D^*,†^ | NM | FACT-G^*^ FACT-Fatigue^*^
Temel, 2010^207^ | cancer | NM | HADS PHQ-9^*,†^ | NM | FACT TOI^*^ FACT-L^*^
Wallen, 2012^208^ | cancer | Gracely Pain Scale^*^ Symptom Distress Scale^*^ | CES-D^*,†^ | NM | NM
Wong, 2016^209^ | heart failure | NM | NM | NM | MQOL Chronic HF Questionnaire^*^ ESAS
Zimmer, 1984 & 1985^210, 211^ | mixed | NM | NM | McCusker scale^*,†^ | NM
Zimmermann, 2014^212^ | cancer | NM | NM | FAMCARE-P16 CARES-MIS^*^ | ESAS FACIT-Sp^*^ QUAL-E

BPI=Brief Pain Inventory;CHF=congestive heart failure; HIV=human immunodeficiency virus; ICU=intensive care unit; MS=multiple sclerosis; CES-D=Center for Epidemiologic Studies Depression Scale; CSDD= Cornell Scale for Depression in Dementia; EORTC QLQ-C30=European Organization for Research and Treatment of Cancer Quality of Life Questionnaire-30 items; EQ-5D=EuroQol; ESAS=Edmonton Symptom Assessment Scale; FACIT-Pal=Functional Assessment of Chronic Illness Therapy-Palliative sub scale; FACT-B= Functional Assessment of Cancer Therapy - Breast Cancer; FACT-G= Functional Assessment of Cancer Therapy - General; FACT-L= Functional Assessment of Cancer Therapy-Lung; FAMCARE-P16= Family Satisfaction with Advanced Cancer Care (16 item version); FLACC= Faces Legs Activity Cry Consolability Behavioral Pain Scale; GHQ-12 =General Health Questionnaire-12 item; HADS =Hospital Anxiety and Depression Scale; ICU=intensive care unit; KCCQ= The Kansas City Cardiomyopathy Questionnaire; LASA= Linear Analogue Scale Assessment; MCOHPQ= Modified City of Hope Patient Questionnaire; MOS-Medical Outcomes Study; MOS-HIV=Medical Outcomes Study HIV Health Survey; MPAC=Memorial Pain Assessment Card; MQOL=McGill Quality of Life Questionnaire; MS= MS Palliative Outcome Scale-S5; MSAS=Memorial Symptom Assessment Scale; MVQOLI-R=Missoula-VITAS Quality of Life Index; NRS= Numeric rating scale; NRS= Numerical Rating Scale; PAINAD= Pain in Advanced Dementia; PHQ-9=Patient Health Queationnaire-9; POMS=Profile of Mood States; QUAL-E=Quality of life at the end of life; SF-12=Short Form 12; SF-36=Short Form 36 Health Survey; TOI=Trial Outcome Index (sum of selected FACT subscales),; UCSD SOBQ =University of California San Diego Shortness of Breath Questionnaire; VAS=Visual Analogue Scale; WONCA=World Organization of National Colleges, Academies and Academic Association of General Practitioners. NM=no measures specific for that domain (note that multidimensional tools of patient experience and quality of life may address these domains).

* Indicates tool that was not identified in the systematic review of assessment tools for this domain.

† Indicates tool that was found during supplemental search.

## References

1 Piderman KM, Kung S, Jenkins SM, . Respecting the spiritual side of advanced cancer care: a systematic review. Curr Oncol Rep. 2015 Feb; 17(2):6. doi: 10.1007/s11912-014-0429-6. PMID: 25681038.25681038
2 Dorman S, Byrne A, Edwards A. Which measurement scales should we use to measure breathlessness in palliative care? A systematic review. Palliat Med. 2007 Apr;21(3): 177-91. doi: 10.1177/0269216307076398. PMID: 17363394.17363394
3 Gift AG. Validation of a vertical visual analogue scale as a measure of clinical dyspnea. Rehabil Nurs 1989 Nov-Dec;14(6):323-5. PMID: 2813949.2813949
4 Gift AG, Narsavage G. Validity of the numeric rating scale as a measure of dyspnea. Am J Crit Care. 1998 May;7(3):200-4. PMID: 9579246.9579246
5 Tanaka K, Akechi T, Okuyama T, . Prevalence and screening of dyspnea interfering with daily life activities in ambulatory patients with advanced lung cancer. J Pain Symptom Manage. 2002 Jun;23(6):484-9. PMID: 12067772.12067772
6 G B. A category scale with ratio properties for intermodal and interindividual comparisons. Psychosocial Judgements and the Process of Perception. Berlin: Deutscher Verlag; 1982.
7 Borg G. Perceived exertion as an indicator of somatic stress. Scand J Rehabil Med. 1970;2(2):92-8. PMID: 5523831.5523831
8 Simon PM, Schwartzstein RM, Weiss JW, . Distinguishable types of dyspnea in patients with shortness of breath. Am Rev Respir Dis. 1990 Nov; 142(5): 1009-14. doi: 10.1164/ajrccm/142.5.1009. PMID: 2240820.2240820
9 Powers J, Bennett SJ. Measurement of dyspnea in patients treated with mechanical ventilation. Am J Crit Care. 1999 Jul;8(4):254-61. PMID: 10392226.10392226
10 Parshall MB, Welsh JD, Brockopp DY, . Reliability and validity of dyspnea sensory quality descriptors in heart failure patients treated in an emergency department. Heart Lung 2001 Jan-Feb;30(1):57-65. doi: 10.1067/mhl.2001.112499. PMID: 11174368.11174368
11 Parshall MB. Psychometric characteristics of dyspnea descriptor ratings in emergency department patients with exacerbated chronic obstructive pulmonary disease. Res Nurs Health. 2002 Oct;25(5):331-44. doi: 10.1002/nur.10051. PMID: 12221688.12221688
12 Heyse-Moore L. On dysonoea in advanced cancer. South Hampton University; 1993.
13 Cedarbaum JM, Stambler N, Malta E, . The ALSFRS-R: a revised ALS functional rating scale that incorporates assessments of respiratory function. BDNF ALS Study Group (Phase III). J Neurol Sci. 1999 Oct 31;169(1-2):13-21. PMID: 10540002.10540002
14 Ferris B. Recommended respiratory disease questionnaire for use with adults and children in epidemiological research. American Review of Respiratory Disease. 1978;118:7-53.354446
15 Leidy NK, Schmier JK, Jones MK, . Evaluating symptoms in chronic obstructive pulmonary disease: validation of the Breathlessness, Cough and Sputum Scale. Respir Med. 2003 Jan;97 Suppl A:S59-70. PMID: 12564612.12564612
16 Guyatt GH, Nogradi S, Halcrow S, . Development and testing of a new measure of health status for clinical trials in heart failure. J Gen Intern Med 1989 Mar-Apr;4(2):101-7. PMID: 2709167.2709167
17 Lewin RJ, Thompson DR, Martin CR, . Validation of the Cardiovascular Limitations and Symptoms Profile (CLASP) in chronic stable angina. J Cardiopulm Rehabil 2002 May-Jun;22(3): 184-91. PMID: 12042687.12042687
18 Selim AJ, Ren XS, Fincke G, . A symptom-based measure of the severity of chronic lung disease: results from the Veterans Health Study. Chest. 1997 Jun; 111(6): 1607-14. PMID: 9187183.9187183
19 Guyatt GH, Berman LB, Townsend M, . A measure of quality of life for clinical trials in chronic lung disease. Thorax. 1987 Oct;42(10):773-8. PMID: 3321537.3321537
20 Schunemann HJ, Griffith L, Jaeschke R, . A comparison of the original chronic respiratory questionnaire with a standardized version. Chest. 2003 Oct; 124(4): 1421-9. PMID: 14555575.14555575
21 Bergman B, Aaronson NK, Ahmedzai S, . The EORTC QLQ-LC13: a modular supplement to the EORTC Core Quality of Life Questionnaire (QLQ-C30) for use in lung cancer clinical trials. EORTC Study Group on Quality of Life. Eur J Cancer. 1994;30A(5):635-42. PMID: 8080679.8080679
22 Garrod R, Bestall JC, Paul EA, . Development and validation of a standardized measure of activity of daily living in patients with severe COPD: the London Chest Activity of Daily Living scale (LCADL). Respir Med. 2000 Jun;94(6):589-96. doi: 10.1053/rmed.2000.0786. PMID: 10921765.10921765
23 Dougan CF, Connell CO, Thornton E, . Development of a patient-specific dyspnoea questionnaire in motor neurone disease (MND): the MND dyspnoea rating scale (MDRS). J Neurol Sci. 2000 Nov 1;180(1-2):86-93. PMID: 11090871.11090871
24 Fairbairn AS, Wood CH, Fletcher CM. Variability in answers to a questionnaire on respiratory symptoms. Br J Prev Soc Med. 1959 Oct;13:175-93. PMID: 13821340.13821340
25 McGavin CR, Artvinli M, Naoe H, . Dyspnoea, disability, and distance walked: comparison of estimates of exercise performance in respiratory disease. Br Med J. 1978 Jul 22;2(6132):241-3. PMID: 678885.678885
26 Lareau SC, Carrieri-Kohlman V, Janson-Bjerklie S, . Development and testing of the Pulmonary Functional Status and Dyspnea Questionnaire (PFSDQ). Heart Lung 1994 May-Jun;23(3):242-50. PMID: 8039994.8039994
27 Rosenthal M, Lohr KN, Rubenstein RS, . Congestive heart failure. Santa Monica, CA: Rand Corporation; 1981.
28 Jones PW, Quirk FH, Baveystock CM, . A self-complete measure of health status for chronic airflow limitation. The St. George's Respiratory Questionnaire. Am Rev Respir Dis. 1992 Jun;145(6):1321-7. doi: 10.1164/ajrccm/145.6.1321. PMID: 1595997.1595997
29 Lee L, Friesen M, Lambert IR, . Evaluation of dyspnea during physical and speech activities in patients with pulmonary diseases. Chest. 1998 Mar; 113(3):625-32. PMID: 9515835.9515835
30 Eakin EG, Resnikoff PM, Prewitt LM, . Validation of a new dyspnea measure: the UCSD Shortness of Breath Questionnaire. University of California, San Diego. Chest. 1998 Mar;113(3):619-24. PMID: 9515834.9515834
31 Ziegler L, Hill K, Neilly L, . Identifying psychological distress at key stages of the cancer illness trajectory: a systematic review of validated self-report measures. J Pain Symptom Manage. 2011 Mar;41(3):619-36. doi: 10.1016/j.jpainsymman.2010.06.024. PMID: 21310585.21310585
32 Love AW, Grabsch B, Clarke DM, . Screening for depression in women with metastatic breast cancer: a comparison of the Beck Depression Inventory Short Form and the Hospital Anxiety and Depression Scale. Aust N Z J Psychiatry. 2004 Jul;38(7):526-31. doi: 10.1111/j.1440-1614.2004.01385.x. PMID: 15255825.15255825
33 Akechi T, Okuyama T, Sugawara Y, . Major depression, adjustment disorders, and post-traumatic stress disorder in terminally ill cancer patients: associated and predictive factors. J Clin Oncol. 2004 May 15;22(10): 1957-65. doi: 10.1200/jco.2004.08.149. PMID: 15143090.15143090
34 Thekkumpurath P, Venkateswaran C, Kumar M, . Screening for psychological distress in palliative care: performance of touch screen questionnaires compared with semistructured psychiatric interview. J Pain Symptom Manage. 2009 Oct;38(4):597-605. doi: 10.1016/j.jpainsymman.2009.01.004. PMID: 19692204.19692204
35 Lloyd-Williams M, Shiels C, Dowrick C. The development of the Brief Edinburgh Depression Scale (BEDS) to screen for depression in patients with advanced cancer. J Affect Disord. 2007 Apr;99(1-3):259-64. doi: 10.1016/j.jad.2006.09.015. PMID: 17055588.17055588
36 Okamura M, Yamawaki S, Akechi T, . Psychiatric disorders following first breast cancer recurrence: prevalence, associated factors and relationship to quality of life. Jpn J Clin Oncol. 2005 Jun;35(6):302-9. doi: 10.1093/jjco/hyi097. PMID: 15961434.15961434
37 Michels CT, Boulton M, Adams A, . Psychometric properties of carer-reported outcome measures in palliative care: A systematic review. Palliat Med. 2016 Jan;30(1):23-44. doi: 10.1177/0269216315601930. PMID: 26407683.26407683
38 Dumont S, Fillion L, Gagnon P, . A new tool to assess family caregivers' burden during end-of-life care. J Palliat Care. 2008 Autumn;24(3):151-61. PMID: 18942565.18942565
39 Cameron JI, Franche RL, Cheung AM, . Lifestyle interference and emotional distress in family caregivers of advanced cancer patients. Cancer. 2002 Jan 15;94(2):521-7. doi: 10.1002/cncr.10212. PMID: 11900237.11900237
40 Weitzner MA, McMillan SC, Jacobsen PB. Family caregiver quality of life: differences between curative and palliative cancer treatment settings. J Pain Symptom Manage. 1999 Jun;17(6):418-28. PMID: 10388247.10388247
41 Hudson PL, Hayman-White K. Measuring the psychosocial characteristics of family caregivers of palliative care patients: psychometric properties of nine self-report instruments. J Pain Symptom Manage. 2006 Mar;31(3):215-28. doi: 10.1016/j.jpainsymman.2005.07.010. PMID: 16563316.16563316
42 Hwang SS, Chang VT, Alejandro Y, . Caregiver unmet needs, burden, and satisfaction in symptomatic advanced cancer patients at a Veterans Affairs (VA) medical center. Palliat Support Care. 2003 Dec; 1(4):319-29. PMID: 16594221.16594221
43 Cooper B, Kinsella GJ, Picton C. Development and initial validation of a family appraisal of caregiving questionnaire for palliative care. Psychooncology. 2006 Jul;15(7):613-22. doi: 10.1002/pon.1001.PMID: 16287207.16287207
44 Cohen R, Leis AM, Kuhl D, . QOLLTI-F: measuring family carer quality of life. Palliat Med. 2006 Dec;20(8):755-67. doi: 10.1177/0269216306072764. PMID: 17148530.17148530
45 Higginson IJ, Gao W, Jackson D, . Short-form Zarit Caregiver Burden Interviews were valid in advanced conditions. J Clin Epidemiol. 2010 May;63(5):535-42. doi: 10.1016/j.jclinepi.2009.06.014. PMID: 19836205.19836205
46 Selman L, Siegert R, Harding R, . A psychometric evaluation of measures of spirituality validated in culturally diverse palliative care populations. J Pain Symptom Manage. 2011 Oct;42(4):604-22. doi: 10.1016/j.jpainsymman.2011.01.015. PMID: 21640549.21640549
47 Rosenfeld B, Gibson C, Kramer M, . Hopelessness and terminal illness: the construct of hopelessness in patients with advanced AIDS. Palliat Support Care. 2004 Mar;2(1):43-53. PMID: 16594234.16594234
48 Nissim R, Flora DB, Cribbie RA, . Factor structure of the Beck Hopelessness Scale in individuals with advanced cancer. Psychooncology. 2010 Mar;19(3):255-63. doi: 10.1002/pon.1540. PMID: 19274620.19274620
49 Abbey JG, Rosenfeld B, Pessin H, . Hopelessness at the end of life: the utility of the hopelessness scale with terminally ill cancer patients. Br J Health Psychol. 2006 May;11(Pt 2): 173-83. doi: 10.1348/135910705x36749. PMID: 16643692.16643692
50 Ironson G, Solomon GF, Balbin EG, . The Ironson-woods Spirituality/Religiousness Index is associated with long survival, health behaviors, less distress, and low cortisol in people with HIV/AIDS. Ann Behav Med. 2002 Winter;24(1):34-48. PMID: 12008793.12008793
51 Sealey M, Breen LJ, O'Connor M, . A scoping review of bereavement risk assessment measures: Implications for palliative care. Palliat Med. 2015 Jul;29(7):577-89. doi: 10.1177/0269216315576262. PMID: 25805738.25805738
52 Guarnaccia CA, B H. Factor structure of the bereavement experience questionnaire: the BEQ-24, a revised short-form. Omega. 1998;37:303-16.
53 Shear KM, Jackson CT, Essock SM, . Screening for complicated grief among Project Liberty service recipients 18 months after September 11, 2001. Psychiatr Serv. 2006 Sep;57(9):1291-7. doi: 10.1176/appi.ps.57.9.1291. PMID: 16968758.16968758
54 Ito M, Nakajima S, Fujisawa D, . Brief measure for screening complicated grief: reliability and discriminant validity. PLoS One. 2012;7(2):e31209. doi: 10.1371/journal.pone.0031209. PMID: 22348057.22348057
55 Fujisawa D, Miyashita M, Nakajima S, . Prevalence and determinants of complicated grief in general population. J Affect Disord. 2010 Dec;127(1-3):352-8. doi: 10.1016/j.jad.2010.06.008. PMID: 20580096.20580096
56 Burnett P, Middleton W, Raphael B, . Measuring core bereavement phenomena. Psychol Med. 1997 Jan;27(1):49-57. PMID: 9122308.9122308
57 Jordan JR, Baker J, Matteis M, . The grief evaluation measure (GEM): an initial validation study. Death Stud. 2005 May;29(4):301-32. doi: 10.1080/07481180590923706. PMID: 15849881.15849881
58 Barrett TW, Scott TB. Development of the Grief Experience Questionnaire. Suicide Life Threat Behav. 1989 Summer;19(2):201-15. PMID: 2749862.2749862
59 Hogan NS, Greenfield DB, Schmidt LA. Development and validation of the Hogan Grief Reaction Checklist. Death Stud 2001 Jan-Feb;25(1):1-32. doi: 10.1080/07481180125831. PMID: 11503760.11503760
60 Prigerson HG, Maciejewski PK, Reynolds CF, 3rd, . Inventory of Complicated Grief: a scale to measure maladaptive symptoms of loss. Psychiatry Res. 1995 Nov 29;59(1-2):65-79. PMID: 8771222.8771222
61 Prigerson HG, Horowitz MJ, Jacobs SC, . Prolonged grief disorder: Psychometric validation of criteria proposed for DSM-V and ICD-11. PLoS Med. 2009 Aug;6(8):e1000121. doi: 10.1371/journal.pmed.1000121. PMID: 19652695.19652695
62 O'Connor M, Lasgaard M, Shevlin M, . A confirmatory factor analysis of combined models of the Harvard Trauma Questionnaire and the Inventory of Complicated Grief-Revised: are we measuring complicated grief or posttraumatic stress? J Anxiety Disord. 2010 Oct;24(7):672-9. doi: 10.1016/j.janxdis.2010.04.009. PMID: 20510576.20510576
63 Guldin MB, O'Connor M, Sokolowski I, . Identifying bereaved subjects at risk of complicated grief: Predictive value of questionnaire items in a cohort study. BMC Palliat Care. 2011;10:9. doi: 10.1186/1472-684x-10-9. PMID: 21575239.21575239
64 Prigerson HG, SC J. Traumatic grief as a distinct disorder: a rationale, consensus criteria, and a preliminary empirical test. In: Stroebe MS, Hansson RO, Stroebe W, . (eds) Handbook of bereavement research: consequences, coping, and care. Washington, DC: American Psychological Association; 2001.
65 Marwit SJ, Meuser TM. Development and initial validation of an inventory to assess grief in caregivers of persons with Alzheimer's disease. Gerontologist. 2002 Dec;42(6):751-65. PMID: 12451156.12451156
66 Marwit SJ, Kaye PN. Measuring grief in caregivers of persons with acquired brain injury. Brain Inj. 2006 Dec;20(13-14): 1419-29. PMID: 17378234.17378234
67 Marwit SJ, Chibnall JT, Dougherty R, . Assessing pre-death grief in cancer caregivers using the Marwit-Meuser Caregiver Grief Inventory (MM-CGI). Psychooncology. 2008 Mar;17(3):300-3. doi: 10.1002/pon.1218. PMID: 17518412.17518412
68 Marwit SJ, Meuser TM. Development of a short form inventory to assess grief in caregivers of dementia patients. Death Stud. 2005 Apr;29(3): 191-205. doi: 10.1080/07481180590916335. PMID: 15816111.15816111
69 Kiely DK, Prigerson H, Mitchell SL. Health care proxy grief symptoms before the death of nursing home residents with advanced dementia. Am J Geriatr Psychiatry. 2008 Aug;16(8):664-73. doi: 10.1097/JGP.0b013e3181784143. PMID: 18669945.18669945
70 Lai C, Luciani M, Morelli E, . Predictive role of different dimensions of burden for risk of complicated grief in caregivers of terminally ill patients. Am J Hosp Palliat Care. 2014 Mar;31(2):189-93. doi: 10.1177/1049909113490227. PMID: 23689368.23689368
71 Lichtenthal WG, Nilsson M, Kissane DW, . Underutilization of mental health services among bereaved caregivers with prolonged grief disorder. Psychiatr Serv. 2011 Oct;62(10): 1225-9. doi: 10.1176/appi.ps.62.10.1225 10.1176/ps.62.10.pss6210_1225. PMID: 21969652.21969652
72 Papa A, Lancaster NG, Kahler J. Commonalities in grief responding across bereavement and non-bereavement losses. J Affect Disord. 2014 Jun;161:136-43. doi: 10.1016/j.jad.2014.03.018. PMID: 24751321.24751321
73 Lev E, Munro BH, McCorkle R. A shortened version of an instrument measuring bereavement. Int J Nurs Stud. 1993 Jun;30(3):213-26. PMID: 8335431.8335431
74 Faschingbauer T, DeVaul RA, S Z. The Texas Revised Inventory of Grief. In: Zisook S (ed.) Biopsychosocial aspects of bereavement. Washington, DC: American Psychiatric Press, Inc.; 1987.
75 Zisook S, Devaul RA, Click MA, Jr. Measuring symptoms of grief and bereavement. Am J Psychiatry. 1982 Dec; 139(12):1590-3. doi: 10.1176/ajp.139.12.1590. PMID: 7149059.7149059
76 Faschingbauer TR, Devaul RA, Zisook S. Development of the Texas Inventory of Grief. Am J Psychiatry. 1977 Jun;134(6):696-8. doi: 10.1176/ajp.134.6.696. PMID: 869041.869041
77 Futterman A, Holland JM, Brown PJ, . Factorial validity of the Texas Revised Inventory of Grief-Present scale among bereaved older adults. Psychol Assess. 2010 Sep;22(3):675-87. doi: 10.1037/a0019914. PMID: 20822280.20822280
78 Rubin SS, Nadav OB, Malkinson R, . The two-track model of bereavement questionnaire (TTBQ): development and validation of a relational measure. Death Stud. 2009 Apr;33(4):305-33. doi: 10.1080/07481180802705668. PMID: 19368062.19368062
79 Assessing complicated grief using the Two-Track Bereavement Questionnaire (TTBQ). The 10th international conference on Grief and Bereavement in Contemporary Society: East meets West expanding frontiers and diversity; 2014 Hong Kong. p. 54.
80 Albers G, Echteld MA, de Vet HC, . Evaluation of quality-of-life measures for use in palliative care: a systematic review. Palliat Med. 2010 Jan;24(1):17-37. doi: 10.1177/0269216309346593. PMID: 19843620.19843620
81 Guo H, Fine PG, Mendoza TR, . A preliminary study of the utility of the brief hospice inventory. J Pain Symptom Manage. 2001 Aug;22(2):637-48. PMID: 11495710.11495710
82 Ewing G, Todd C, Rogers M, . Validation of a symptom measure suitable for use among palliative care patients in the community: CAMPAS-R. J Pain Symptom Manage. 2004 Apr;27(4):287-99. doi: 10.1016/j.jpainsymman.2003.12.012. PMID: 15050656.15050656
83 Kissane DW, Wein S, Love A, . The Demoralization Scale: a report of its development and preliminary validation. J Palliat Care. 2004 Winter;20(4):269-76. PMID: 15690829.15690829
84 Kaasa T, Loomis J, Gillis K, . The Edmonton Functional Assessment Tool: preliminary development and evaluation for use in palliative care. J Pain Symptom Manage. 1997 Jan;13(1):10-9. PMID: 9029857.9029857
85 Kaasa T, Wessel J. The Edmonton Functional Assessment Tool: further development and validation for use in palliative care. J Palliat Care. 2001 Spring;17(1):5-11. PMID: 11324186.11324186
86 Schwartz CE, Merriman MP, Reed GW, . Measuring patient treatment preferences in end-of-life care research: applications for advance care planning interventions and response shift research. J Palliat Med. 2004 Apr;7(2):233-45. doi: 10.1089/109662104773709350. PMID: 15130201.15130201
87 Blazeby JM, Conroy T, Hammerlid E, . Clinical and psychometric validation of an EORTC questionnaire module, the EORTC QLQ-OES18, to assess quality of life in patients with oesophageal cancer. Eur J Cancer. 2003 Jul;39(10):1384-94. PMID: 12826041.12826041
88 Blazeby JM, Conroy T, Bottomley A, . Clinical and psychometric validation of a questionnaire module, the EORTC QLQ-STO 22, to assess quality of life in patients with gastric cancer. Eur J Cancer. 2004 Oct;40(15):2260-8. doi: 10.1016/j.ejca.2004.05.023. PMID: 15454251.15454251
89 Chang VT, Hwang SS, Feuerman M. Validation of the Edmonton Symptom Assessment Scale. Cancer. 2000 May 1;88(9):2164-71. PMID: 10813730.10813730
90 Lyons KD, Bakitas M, Hegel MT, . Reliability and validity of the Functional Assessment of Chronic Illness Therapy-Palliative care (FACIT-Pal) scale. J Pain Symptom Manage. 2009 Jan;37(1):23-32. doi: 10.1016/j.jpainsymman.2007.12.015. PMID: 18504093.18504093
91 McMillan SC, Weitzner M. Quality of life in cancer patients: use of a revised Hospice Index. Cancer Pract 1998 Sep-Oct;6(5):282-8. PMID: 9767348.9767348
92 McMillan SC, Dunbar SB, W Z. Validation of the Hospice Quality-of-Life Index and the Constipation Assessment Scale in end-stage cardiac disease patients in hospice care. J Hosp Palliat Nurs. 2008;10:106-17.
93 Dobratz MC. The life closure scale: additional psychometric testing of a tool to measure psychological adaptation in death and dying. Res Nurs Health. 2004 Feb;27(1):52-62. doi: 10.1002/nur.20003. PMID: 14745856.14745856
94 Salmon P, Manzi F, Valori RM. Measuring the meaning of life for patients with incurable cancer: the life evaluation questionnaire (LEQ). Eur J Cancer. 1996 May;32A(5):755-60. PMID: 9081350.9081350
95 Sterkenburg CA, King B, Woodward CA. A reliability and validity study of the McMaster Quality of Life Scale (MQLS) for a palliative population. J Palliat Care. 1996 Spring;12(1):18-25. PMID: 8857243.8857243
96 Cohen SR, Mount BM, Bruera E, . Validity of the McGill Quality of Life Questionnaire in the palliative care setting: a multi-centre Canadian study demonstrating the importance of the existential domain. Palliat Med. 1997 Jan;11(1):3-20. PMID: 9068681.9068681
97 Cohen SR, Mount BM. Living with cancer: “good” days and “bad” days--what produces them? Can the McGill quality of life questionnaire distinguish between them? Cancer. 2000 Oct 15;89(8):1854-65. PMID: 11042583.11042583
98 Lua PL, Salek S, Finlay I, . The feasibility, reliability and validity of the McGill Quality of Life Questionnaire-Cardiff Short Form (MQOL-CSF) in palliative care population. Qual Life Res. 2005 Sep;14(7):1669-81. PMID: 16119179.16119179
99 McCanse RP. The McCanse Readiness for Death Instrument (MRDI): a reliable and valid measure for hospice care. Hosp J. 1995;10(1):15-26. PMID: 7789938.7789938
100 Sherman DW, Ye XY, Beyer McSherry C, . Symptom assessment of patients with advanced cancer and AIDS and their family caregivers: the results of a quality-of-life pilot study. Am J Hosp Palliat Care 2007 Oct-Nov;24(5):350-65. doi: 10.1177/1049909106299063. PMID: 17998406.17998406
101 Lobchuk MM. The memorial symptom assessment scale: modified for use in understanding family caregivers' perceptions of cancer patients' symptom experiences. J Pain Symptom Manage. 2003 Jul;26(1):644-54. PMID: 12850647.12850647
102 Chang VT, Hwang SS, Kasimis B, . Shorter symptom assessment instruments: the Condensed Memorial Symptom Assessment Scale (CMSAS). Cancer Invest. 2004;22(4):526-36. PMID: 15565810.15565810
103 Hickman SE, Tilden VP, Tolle SW. Family reports of dying patients' distress: the adaptation of a research tool to assess global symptom distress in the last week of life. J Pain Symptom Manage. 2001 Jul;22(1):565-74. PMID: 11516598.11516598
104 Byock IR, Merriman MP. Measuring quality of life for patients with terminal illness: the Missoula-VITAS quality of life index. Palliat Med. 1998 Jul;12(4):231-44. PMID: 9743822.9743822
105 Schwartz CE, Merriman MP, Reed G, . Evaluation of the Missoula-VITAS Quality of Life Index--revised: research tool or clinical tool? J Palliat Med. 2005 Feb;8(1):121-35. doi: 10.1089/jpm.2005.8.121. PMID: 15662181.15662181
106 Rainbird KJ, Perkins JJ, Sanson-Fisher RW. The Needs Assessment for Advanced Cancer Patients (NA-ACP): a measure of the perceived needs of patients with advanced, incurable cancer. a study of validity, reliability and acceptability. Psychooncology. 2005 Apr;14(4):297-306. doi: 10.1002/pon.845. PMID: 15386766.15386766
107 Vernooij-Dassen MJ, Osse BH, Schade E, . Patient autonomy problems in palliative care: systematic development and evaluation of a questionnaire. J Pain Symptom Manage. 2005 Sep;30(3):264-70. doi: 10.1016/j.jpainsymman.2005.03.010. PMID: 16183010.16183010
108 Chochinov HM, Hassard T, McClement S, . The patient dignity inventory: a novel way of measuring dignity-related distress in palliative care. J Pain Symptom Manage. 2008 Dec;36(6):559-71. doi: 10.1016/j.jpainsymman.2007.12.018. PMID: 18579340.18579340
109 Osse BH, Vernooij MJ, Schade E, . Towards a new clinical tool for needs assessment in the palliative care of cancer patients: the PNPC instrument. J Pain Symptom Manage. 2004 Oct;28(4):329-41. doi: 10.1016/j.jpainsymman.2004.01.010. PMID: 15471650.15471650
110 Osse BH, Vernooij-Dassen MJ, Schade E, . A practical instrument to explore patients' needs in palliative care: the Problems and Needs in Palliative Care questionnaire short version. Palliat Med. 2007 Jul;21(5):391-9. doi: 10.1177/0269216307078300. PMID: 17901098.17901098
111 Hearn J, Higginson IJ. Development and validation of a core outcome measure for palliative care: the palliative care outcome scale. Palliative Care Core Audit Project Advisory Group. Qual Health Care. 1999 Dec;8(4):219-27. PMID: 10847883.10847883
112 Steinhauser KE, Clipp EC, Bosworth HB, . Measuring quality of life at the end of life: validation of the QUAL-E. Palliat Support Care. 2004 Mar;2(1):3-14. PMID: 16594230.16594230
113 Hermann C. Development and testing of the spiritual needs inventory for patients near the end of life. Oncol Nurs Forum. 2006 Jul;33(4):737-44. doi: 10.1188/06.onf.737-744. PMID: 16858454.16858454
114 Lendon JP, Ahluwalia SC, Walling AM, . Measuring Experience With End-of-Life Care: A Systematic Literature Review. J Pain Symptom Manage. 2015 May;49(5):904-15 e1-3. doi: 10.1016/j.jpainsymman.2014.10.018. PMID: 25543110.25543110
115 Arcand M, Monette J, Monette M, . Educating nursing home staff about the progression of dementia and the comfort care option: impact on family satisfaction with end-of-life care. J Am Med Dir Assoc. 2009 Jan;10(1):50-5. doi: 10.1016/j.jamda.2008.07.008. PMID: 19111853.19111853
116 Baker R, Wu AW, Teno JM, . Family satisfaction with end-of-life care in seriously ill hospitalized adults. J Am Geriatr Soc. 2000 May;48(5 Suppl):S61-9. PMID: 10809458.10809458
117 Bakitas M, Ahles TA, Skalla K, . Proxy perspectives regarding end-of-life care for persons with cancer. Cancer. 2008 Apr 15;112(8):1854-61. doi: 10.1002/cncr.23381. PMID: 18306393.18306393
118 Cohen LW, van der Steen JT, Reed D, . Family perceptions of end-of-life care for long-term care residents with dementia: differences between the United States and the Netherlands. J Am Geriatr Soc. 2012 Feb;60(2):316-22. doi: 10.1111/j.1532-5415.2011.03816.x. PMID: 22288500.22288500
119 Gelfman LP, Meier DE, Morrison RS. Does palliative care improve quality? A survey of bereaved family members. J Pain Symptom Manage. 2008 Jul;36(1):22-8. doi: 10.1016/j.jpainsymman.2007.09.008. PMID: 18411019.18411019
120 Hallenbeck J, Hickey E, Czarnowski E, . Quality of care in a Veterans Affairs' nursing home-based hospice unit. J Palliat Med. 2007 Feb;10(1):127-35. doi: 10.1089/jpm.2006.0141. PMID: 17298261.17298261
121 Shega JW, Hougham GW, Stocking CB, . Patients dying with dementia: experience at the end of life and impact of hospice care. J Pain Symptom Manage. 2008 May;35(5):499-507. doi: 10.1016/j.jpainsymman.2007.06.011. PMID: 18261878.18261878
122 Teno JM, Clarridge B, Casey V, . Validation of Toolkit After-Death Bereaved Family Member Interview. J Pain Symptom Manage. 2001 Sep;22(3):752-8. PMID: 11532588.11532588
123 Kiely DK, Volicer L, Teno J, . The validity and reliability of scales for the evaluation of end-of-life care in advanced dementia. Alzheimer Dis Assoc Disord 2006 Jul-Sep;20(3):176-81. PMID: 16917188.16917188
124 van der Steen JT, Gijsberts MJ, Muller MT, . Evaluations of end of life with dementia by families in Dutch and U.S. nursing homes. Int Psychogeriatr. 2009 Apr;21(2):321-9. doi: 10.1017/s1041610208008399. PMID: 19193253.19193253
125 Alici Y, Smith D, Lu HL, . Families' perceptions of veterans' distress due to post-traumatic stress disorder-related symptoms at the end of life. J Pain Symptom Manage. 2010 Mar;39(3):507-14. doi: 10.1016/j.jpainsymman.2009.07.011. PMID: 20083372.20083372
126 Casarett D, Shreve S, Luhrs C, . Measuring families' perceptions of care across a health care system: preliminary experience with the Family Assessment of Treatment at End of Life Short form (FATE-S). J Pain Symptom Manage. 2010 Dec;40(6):801-9. doi: 10.1016/j.jpainsymman.2010.03.019. PMID: 20813493.20813493
127 Finlay E, Shreve S, Casarett D. Nationwide veterans affairs quality measure for cancer: the family assessment of treatment at end of life. J Clin Oncol. 2008 Aug 10;26(23):3838-44. doi: 10.1200/jco.2008.16.8534. PMID: 18688050.18688050
128 Lu H, Trancik E, Bailey FA, . Families' perceptions of end-of-life care in Veterans Affairs versus non-Veterans Affairs facilities. J Palliat Med. 2010 Aug;13(8):991-6. doi: 10.1089/jpm.2010.0044. PMID: 20649437.20649437
129 Smith D, Caragian N, Kazlo E, . Can we make reports of end-of-life care quality more consumer-focused? results of a nationwide quality measurement program. J Palliat Med. 2011 Mar;14(3):301-7. doi: 10.1089/jpm.2010.0321. PMID: 21288125.21288125
130 Connor SR, Teno J, Spence C, . Family evaluation of hospice care: results from voluntary submission of data via website. J Pain Symptom Manage. 2005 Jul;30(1):9-17. doi: 10.1016/j.jpainsymman.2005.04.001. PMID: 16043002.16043002
131 Mitchell SL, Kiely DK, Miller SC, . Hospice care for patients with dementia. J Pain Symptom Manage. 2007 Jul;34(1):7-16. doi: 10.1016/j.jpainsymman.2007.01.003. PMID: 17509813.17509813
132 Rhodes RL, Mitchell SL, Miller SC, . Bereaved family members' evaluation of hospice care: what factors influence overall satisfaction with services? J Pain Symptom Manage. 2008 Apr;35(4):365-71. doi: 10.1016/j.jpainsymman.2007.12.004. PMID: 18294811.18294811
133 Rhodes RL, Teno JM, Connor SR. African American bereaved family members' perceptions of the quality of hospice care: lessened disparities, but opportunities to improve remain. J Pain Symptom Manage. 2007 Nov;34(5):472-9. doi: 10.1016/j.jpainsymman.2007.06.004. PMID: 17900854.17900854
134 Schockett ER, Teno JM, Miller SC, . Late referral to hospice and bereaved family member perception of quality of end-of-life care. J Pain Symptom Manage. 2005 Nov;30(5):400-7. doi: 10.1016/j.jpainsymman.2005.04.013. PMID: 16310614.16310614
135 Teno JM, Clarridge BR, Casey V, . Family perspectives on end-of-life care at the last place of care. JAMA. 2004 Jan 7;291(1):88-93. doi: 10.1001/jama.291.1.88. PMID: 14709580.14709580
136 Teno JM, Shu JE, Casarett D, . Timing of referral to hospice and quality of care: length of stay and bereaved family members' perceptions of the timing of hospice referral. J Pain Symptom Manage. 2007 Aug;34(2):120-5. doi: 10.1016/j.jpainsymman.2007.04.014. PMID: 17583469.17583469
137 York GS, Jones JL, Churchman R. Understanding the association between employee satisfaction and family perceptions of the quality of care in hospice service delivery. J Pain Symptom Manage. 2009 Nov;38(5):708-16. doi: 10.1016/j.jpainsymman.2009.03.002. PMID: 19699608.19699608
138 Curtis JR, Treece PD, Nielsen EL, . Integrating palliative and critical care: evaluation of a quality-improvement intervention. Am J Respir Crit Care Med. 2008 Aug 1;178(3):269-75. doi: 10.1164/rccm.200802-272OC. PMID: 18480429.18480429
139 Gries CJ, Curtis JR, Wall RJ, . Family member satisfaction with end-of-life decision making in the ICU. Chest. 2008 Mar;133(3):704-12. doi: 10.1378/chest.07-1773. PMID: 18198256.18198256
140 Lewis-Newby M, Curtis JR, Martin DP, . Measuring family satisfaction with care and quality of dying in the intensive care unit: does patient age matter? J Palliat Med. 2011 Dec;14(12):1284-90. doi: 10.1089/jpm.2011.0138. PMID: 22107108.22107108
141 Aoun S, Bird S, Kristjanson LJ, . Reliability testing of the FAMCARE-2 scale: measuring family carer satisfaction with palliative care. Palliat Med. 2010 Oct;24(7):674-81. doi: 10.1177/0269216310373166. PMID: 20621947.20621947
142 Carter GL, Lewin TJ, Gianacas L, . Caregiver satisfaction with out-patient oncology services: utility of the FAMCARE instrument and development of the FAMCARE-6. Support Care Cancer. 2011 Apr;19(4):565-72. doi: 10.1007/s00520-010-0858-1. PMID: 20349317.20349317
143 Lo C, Burman D, Hales S, . The FAMCARE-Patient scale: measuring satisfaction with care of outpatients with advanced cancer. Eur J Cancer. 2009 Dec;45(18):3182-8. doi: 10.1016/j.ejca.2009.09.003. PMID: 19786345.19786345
144 Lo C, Burman D, Rodin G, . Measuring patient satisfaction in oncology palliative care: psychometric properties of the FAMCARE-patient scale. Qual Life Res. 2009 Aug;18(6):747-52. doi: 10.1007/s11136-009-9494-y. PMID: 19513815.19513815
145 Ringdal GI, Jordhoy MS, Kaasa S. Measuring quality of palliative care: psychometric properties of the FAMCARE Scale. Qual Life Res. 2003 Mar;12(2):167-76. PMID: 12639063.12639063
146 Follwell M, Burman D, Le LW, . Phase II study of an outpatient palliative care intervention in patients with metastatic cancer. J Clin Oncol. 2009 Jan 10;27(2):206-13. doi: 10.1200/jco.2008.17.7568. PMID: 19064979.19064979
147 Kristjanson LJ, Leis A, Koop PM, . Family members' care expectations, care perceptions, and satisfaction with advanced cancer care: results of a multi-site pilot study. J Palliat Care. 1997 Winter;13(4):5-13. PMID: 9447806.9447806
148 Meyers JL, Gray LN. The relationships between family primary caregiver characteristics and satisfaction with hospice care, quality of life, and burden. Oncol Nurs Forum 2001 Jan-Feb;28(1):73-82. PMID: 11198900.11198900
149 Mularski R, Curtis JR, Osborne M, . Agreement among family members in their assessment of the Quality of Dying and Death. J Pain Symptom Manage. 2004 Oct;28(4):306-15. doi: 10.1016/j.jpainsymman.2004.01.008. PMID: 15471648.15471648
150 Hales S, Gagliese L, Nissim R, . Understanding bereaved caregiver evaluations of the quality of dying and death: an application of cognitive interviewing methodology to the quality of dying and death questionnaire. J Pain Symptom Manage. 2012 Feb;43(2):195-204. doi: 10.1016/j.jpainsymman.2011.03.018. PMID: 21802895.21802895
151 Johnson KS, Elbert-Avila K, Kuchibhatla M, . Racial differences in next-of-kin participation in an ongoing survey of satisfaction with end-of-life care: a study of a study. J Palliat Med. 2006 Oct;9(5):1076-85. doi: 10.1089/jpm.2006.9.1076. PMID: 17040145.17040145
152 Mularski RA, Heine CE, Osborne ML, . Quality of dying in the ICU: ratings by family members. Chest. 2005 Jul;128(1):280-7. doi: 10.1378/chest.128.1.280. PMID: 16002947.16002947
153 Norris K, Merriman MP, Curtis JR, . Next of kin perspectives on the experience of end-of-life care in a community setting. J Palliat Med. 2007 Oct;10(5):1101-15. doi: 10.1089/jpm.2006.2546. PMID: 17985967.17985967
154 Astrow AB, Wexler A, Texeira K, . Is failure to meet spiritual needs associated with cancer patients' perceptions of quality of care and their satisfaction with care? J Clin Oncol. 2007 Dec 20;25(36):5753-7. doi: 10.1200/jco.2007.12.4362. PMID: 18089871.18089871
155 Sulmasy DP, McIlvane JM. Patients' ratings of quality and satisfaction with care at the end of life. Arch Intern Med. 2002 Oct 14;162(18):2098-104. PMID: 12374518.12374518
156 Sulmasy DP, McIlvane JM, Pasley PM, . A scale for measuring patient perceptions of the quality of end-of-life care and satisfaction with treatment: the reliability and validity of QUEST. J Pain Symptom Manage. 2002 Jun;23(6):458-70. PMID: 12067770.12067770
157 Antunes B, Harding R, Higginson IJ. Implementing patient-reported outcome measures in palliative care clinical practice: a systematic review of facilitators and barriers. Palliat Med. 2014 Feb;28(2):158-75. doi: 10.1177/0269216313491619. PMID: 23801463.23801463
158 Schulman-Green D, Cherlin EJ, McCorkle R, . Benefits and challenges in use of a standardized symptom assessment instrument in hospice. J Palliat Med. 2010 Feb;13(2):155-9. doi: 10.1089/jpm.2009.0245. PMID: 19827961.19827961
159 Escalante CP, Manzullo EF, Lam TP, . Fatigue and its risk factors in cancer patients who seek emergency care. J Pain Symptom Manage. 2008 Oct;36(4):358-66. doi: 10.1016/j.jpainsymman.2007.10.018. PMID: 18411011.18411011
160 Kamel HK, Phlavan M, Malekgoudarzi B, . Utilizing pain assessment scales increases the frequency of diagnosing pain among elderly nursing home residents. J Pain Symptom Manage. 2001 Jun;21(6):450-5. PMID: 11397602.11397602
161 Chang CH, Cella D, Masters GA, . Real-time clinical application of quality-of-life assessment in advanced lung cancer. Clin Lung Cancer. 2002 Sep;4(2):104-9. PMID: 14653866.14653866
162 Clark K, Bardwell WA, Arsenault T, . Implementing touch-screen technology to enhance recognition of distress. Psychooncology. 2009 Aug;18(8):822-30. doi: 10.1002/pon.1509. PMID: 19085974.19085974
163 De Roo ML, Leemans K, Claessen SJ, . Quality indicators for palliative care: update of a systematic review. J Pain Symptom Manage. 2013 Oct;46(4):556-72. doi: 10.1016/j.jpainsymman.2012.09.013. PMID: 23809769.23809769
164 National Quality Forum. National voluntary consensus standards for symptom management and end-of-life care in cancer patients. 2006. http://www.qualityforum.org. Accessed on May 9, 2016.
165 Kavalieratos D, Corbelli J, Zhang D, . Association Between Palliative Care and Patient and Caregiver Outcomes: A Systematic Review and Meta-analysis. 2016;316(20):2104-14. doi: 10.1001/jama.2016.16840. PMID: 27893131.27893131
166 Ahronheim JC, Morrison RS, Morris J, . Palliative care in advanced dementia: a randomized controlled trial and descriptive analysis. J Palliat Med. 2000 Fall;3(3):265-73. doi: 10.1089/jpm.2000.3.265. PMID: 15859668.15859668
167 Aiken LS, Butner J, Lockhart CA, . Outcome evaluation of a randomized trial of the PhoenixCare intervention: program of case management and coordinated care for the seriously chronically ill. J Palliat Med. 2006 Feb;9(1):111-26. doi: 10.1089/jpm.2006.9.111. PMID: 16430351.16430351
168 Bakitas M, Lyons KD, Hegel MT, . Effects of a palliative care intervention on clinical outcomes in patients with advanced cancer: the Project ENABLE II randomized controlled trial. JAMA. 2009 Aug 19;302(7):741-9. doi: 10.1001/jama.2009.1198. PMID: 19690306.19690306
169 Bakitas MA, Tosteson TD, Li Z, . Early Versus Delayed Initiation of Concurrent Palliative Oncology Care: Patient Outcomes in the ENABLE III Randomized Controlled Trial. J Clin Oncol. 2015 May 1;33(13):1438-45. doi: 10.1200/jco.2014.58.6362. PMID: 25800768.25800768
170 Bekelman DB, Plomondon ME, Carey EP, . Primary Results of the Patient-Centered Disease Management (PCDM) for Heart Failure Study: A Randomized Clinical Trial. JAMA Intern Med. 2015 May;175(5):725-32. doi: 10.1001/jamainternmed.2015.0315. PMID: 25822284.25822284
171 Brannstrom M, Boman K. Effects of person-centred and integrated chronic heart failure and palliative home care. PREFER: a randomized controlled study. Eur J Heart Fail. 2014 Oct;16(10):1142-51. doi: 10.1002/ejhf.151. PMID: 25159126.25159126
172 Brumley R, Enguidanos S, Jamison P, . Increased satisfaction with care and lower costs: results of a randomized trial of in-home palliative care. J Am Geriatr Soc. 2007 Jul;55(7):993-1000. doi: 10.1111/j.1532-5415.2007.01234.x. PMID: 17608870.17608870
173 Chapman DG, Toseland RW. Effectiveness of advanced illness care teams for nursing home residents with dementia. Soc Work. 2007 Oct;52(4):321-9. PMID: 18232242.18232242
174 Cheung W, Aggarwal G, Fugaccia E, . Palliative care teams in the intensive care unit: a randomised, controlled, feasibility study. Crit Care Resusc. 2010 Mar;12(1):28-35. PMID: 20196711.20196711
175 Clark MM, Rummans TA, Atherton PJ, . Randomized controlled trial of maintaining quality of life during radiotherapy for advanced cancer. Cancer. 2013 Feb 15;119(4):880-7. doi: 10.1002/cncr.27776. PMID: 22930253.22930253
176 A controlled trial to improve care for seriously ill hospitalized patients. The study to understand prognoses and preferences for outcomes and risks of treatments (SUPPORT). The SUPPORT Principal Investigators. JAMA. 1995 Nov 22-29;274(20):1591-8. PMID: 7474243.7474243
177 Dyar S, Lesperance M, Shannon R, . A nurse practitioner directed intervention improves the quality of life of patients with metastatic cancer: results of a randomized pilot study. J Palliat Med. 2012 Aug;15(8):890-5. doi: 10.1089/jpm.2012.0014. PMID: 22559906.22559906
178 Edmonds P, Hart S, Wei G, . Palliative care for people severely affected by multiple sclerosis: evaluation of a novel palliative care service. Mult Scler. 2010 May;16(5):627-36. doi: 10.1177/1352458510364632. PMID: 20305044.20305044
179 Engelhardt JB, McClive-Reed KP, Toseland RW, . Effects of a program for coordinated care of advanced illness on patients, surrogates, and healthcare costs: a randomized trial. Am J Manag Care. 2006 Feb;12(2):93-100. PMID: 16464138.16464138
180 Farquhar MC, Prevost AT, McCrone P, . Is a specialist breathlessness service more effective and cost-effective for patients with advanced cancer and their carers than standard care? Findings of a mixed-method randomised controlled trial. BMC Med. 2014;12:194. doi: 10.1186/s12916-014-0194-2. PMID: 25358424.25358424
181 Farquhar MC, Prevost AT, McCrone P, . The clinical and cost effectiveness of a Breathlessness Intervention Service for patients with advanced non-malignant disease and their informal carers: mixed findings of a mixed method randomised controlled trial. Trials. 2016;17:185. doi: 10.1186/s13063-016-1304-6. PMID: 27044249.27044249
182 Gade G, Venohr I, Conner D, . Impact of an inpatient palliative care team: a randomized control trial. J Palliat Med. 2008 Mar;11(2):180-90. doi: 10.1089/jpm.2007.0055. PMID: 18333732.18333732
183 Given B, Given CW, McCorkle R, . Pain and fatigue management: results of a nursing randomized clinical trial. Oncol Nurs Forum. 2002 Jul;29(6):949-56. doi: 10.1188/02.onf.949-956. PMID: 12096292.12096292
184 Grande GE, Todd CJ, Barclay SI, . Does hospital at home for palliative care facilitate death at home? Randomised controlled trial. BMJ. 1999 Dec 4;319(7223):1472-5. PMID: 10582932.10582932
185 Grande GE, Todd CJ, Barclay SI, . A randomized controlled trial of a hospital at home service for the terminally ill. Palliat Med. 2000 Sep;14(5):375-85. PMID: 11064784.11064784
186 Grudzen CR, Richardson LD, Johnson PN, . Emergency Department-Initiated Palliative Care in Advanced Cancer: A Randomized Clinical Trial. JAMA Oncol 2016 Jan 14doi: 10.1001/jamaoncol.2015.5252. PMID: 26768772.26768772
187 Hanks GW, Robbins M, Sharp D, . The imPaCT study: a randomised controlled trial to evaluate a hospital palliative care team. Br J Cancer. 2002 Sep 23;87(7):733-9. doi: 10.1038/sj.bjc.6600522. PMID: 12232756.12232756
188 Higginson IJ, Bausewein C, Reilly CC, . An integrated palliative and respiratory care service for patients with advanced disease and refractory breathlessness: a randomised controlled trial. Lancet Respir Med. 2014 Dec;2(12):979-87. doi: 10.1016/s2213-2600(14)70226-7. PMID: 25465642.25465642
189 Hopp FP, Zalenski RJ, Waselewsky D, . Results of a Hospital-Based Palliative Care Intervention for Patients With an Acute Exacerbation of Chronic Heart Failure. J Card Fail 2016 Apr 11doi: 10.1016/j.cardfail.2016.04.004. PMID: 27079676.27079676
190 Hughes SL, Cummings J, Weaver F, . A randomized trial of the cost effectiveness of VA hospital-based home care for the terminally ill. Health Serv Res. 1992 Feb;26(6):801-17. PMID: 1737710.1737710
191 Jordhoy MS, Fayers P, Saltnes T, . A palliative-care intervention and death at home: a cluster randomised trial. Lancet. 2000 Sep 9;356(9233):888-93. PMID: 11036893.11036893
192 Jordhoy MS, Fayers P, Loge JH, . Quality of life in palliative cancer care: results from a cluster randomized trial. J Clin Oncol. 2001 Sep 15;19(18):3884-94. PMID: 11559726.11559726
193 Kane RL, Wales J, Bernstein L, . A randomised controlled trial of hospice care. Lancet. 1984 Apr 21;1(8382):890-4. PMID: 6143195.6143195
194 Kane RL, Klein SJ, Bernstein L, . Hospice role in alleviating the emotional stress of terminal patients and their families. Med Care. 1985 Mar;23(3):189-97. PMID: 3884916.3884916
195 Lowther K, Selman L, Simms V, . Nurse-led palliative care for HIV-positive patients taking antiretroviral therapy in Kenya: a randomised controlled trial. Lancet HIV. 2015 Aug;2(8):e328-34. doi: 10.1016/s2352-3018(15)00111-3. PMID: 26423375.26423375
196 McCorkle R, Benoliel JQ, Donaldson G, . A randomized clinical trial of home nursing care for lung cancer patients. Cancer. 1989 Sep 15;64(6):1375-82. PMID: 2670188.2670188
197 McCorkle R, Jeon S, Ercolano E, . An Advanced Practice Nurse Coordinated Multidisciplinary Intervention for Patients with Late-Stage Cancer: A Cluster Randomized Trial. J Palliat Med. 2015 Nov;18(11):962-9. doi: 10.1089/jpm.2015.0113. PMID: 26305992.26305992
198 Northouse L, Kershaw T, Mood D, . Effects of a family intervention on the quality of life of women with recurrent breast cancer and their family caregivers. Psychooncology. 2005 Jun;14(6):478-91. doi: 10.1002/pon.871. PMID: 15599947.15599947
199 Northouse LL, Mood DW, Schafenacker A, . Randomized clinical trial of a family intervention for prostate cancer patients and their spouses. Cancer. 2007 Dec 15;110(12):2809-18. doi: 10.1002/cncr.23114. PMID: 17999405.17999405
200 Northouse LL, Mood DW, Schafenacker A, . Randomized clinical trial of a brief and extensive dyadic intervention for advanced cancer patients and their family caregivers. Psychooncology. 2013 Mar;22(3):555-63. doi: 10.1002/pon.3036. PMID: 22290823.22290823
201 Pantilat SZ, O'Riordan DL, Dibble SL, . Hospital-based palliative medicine consultation: a randomized controlled trial. Arch Intern Med. 2010 Dec 13;170(22):2038-40. doi: 10.1001/archinternmed.2010.460. PMID: 21149765.21149765
202 Rabow MW, Dibble SL, Pantilat SZ, . The comprehensive care team: a controlled trial of outpatient palliative medicine consultation. Arch Intern Med. 2004 Jan 12;164(1):83-91. doi: 10.1001/archinte.164.1.83. PMID: 14718327.14718327
203 Radwany SM, Hazelett SE, Allen KR, . Results of the promoting effective advance care planning for elders (PEACE) randomized pilot study. Popul Health Manag. 2014 Apr;17(2):106-11. doi: 10.1089/pop.2013.0017. PMID: 24156664.24156664
204 Rummans TA, Clark MM, Sloan JA, . Impacting quality of life for patients with advanced cancer with a structured multidisciplinary intervention: a randomized controlled trial. J Clin Oncol. 2006 Feb 1;24(4):635-42. doi: 10.1200/jco.2006.06.209. PMID: 16446335.16446335
205 Sidebottom AC, Jorgenson A, Richards H, . Inpatient palliative care for patients with acute heart failure: outcomes from a randomized trial. J Palliat Med. 2015 Feb;18(2):134-42. doi: 10.1089/jpm.2014.0192. PMID: 25479182.25479182
206 Steel JL, Geller DA, Kim KH, . Web-based collaborative care intervention to manage cancer-related symptoms in the palliative care setting. Cancer. 2016 Apr 15;122(8):1270-82. doi: 10.1002/cncr.29906. PMID: 26970434.26970434
207 Temel JS, Greer JA, Muzikansky A, . Early palliative care for patients with metastatic non-small-cell lung cancer. N Engl J Med. 2010 Aug 19;363(8):733-42. doi: 10.1056/NEJMoa1000678. PMID: 20818875.20818875
208 Wallen GR, Baker K, Stolar M, . Palliative care outcomes in surgical oncology patients with advanced malignancies: a mixed methods approach. Qual Life Res. 2012 Apr;21(3):405-15. doi: 10.1007/s11136-011-0065-7. PMID: 22101861.22101861
209 Wong FK, Ng AY, Lee PH, . Effects of a transitional palliative care model on patients with end-stage heart failure: a randomised controlled trial. Heart. 2016 Jul 15;102(14):1100-8. doi: 10.1136/heartjnl-2015-308638. PMID: 26969631.26969631
210 Zimmer JG, Groth-Juncker A, McCusker J. Effects of a physician-led home care team on terminal care. J Am Geriatr Soc. 1984 Apr;32(4):288-92. PMID: 6707409.6707409
211 Zimmer JG, Groth-Juncker A, McCusker J. A randomized controlled study of a home health care team. Am J Public Health. 1985 Feb;75(2):134-41. PMID: 3966617.3966617
212 Zimmermann C, Swami N, Krzyzanowska M, . Early palliative care for patients with advanced cancer: a cluster-randomised controlled trial. Lancet. 2014 May 17;383(9930):1721-30. doi: 10.1016/s0140-6736(13)62416-2. PMID: 24559581.24559581