# Appendix I Palliative Care Tools Master List

List of Palliative Care Tools Used Arranged by Domain:

## Domain 1 Structure and Processes

1. McCusker 4-item instrument for continuity
2. Quality of communication questionnaire

## Domain 2 Physical

### Pain

3 MD Anderson Symptom Inventory
4 Family Pain Questionnaire
5 Patient Pain Interview
6 Patient Pain Questionnaire
7 Psychosocial Pain Assessment Form
8 The Breakthrough Pain Questionnaire
9 Brief Pain Inventory
10 City of Hope Mayday Pain Resource Center Pain Audit Tools
11 City of Hope Mayday Pain Resource Center Patient Pain Questionnaire
12 Descriptor Differential Scale
13 Integrated Pain Score
14 McGill Pain Questionnaire
15 Memorial Pain Assessment Card (MPAC)
16 Numerical Rating Scale for pain (NRS)
17 Pain as assessed in the Medical Outcomes Study
18 Pain Disability Index
19 Pain Management Index
20 Pain Perception Profile
21 Patient Outcome Questionnaire
22 Cancer Total Quality Pain Management Patient Assessment Tool (TQPM)
23 Unmet Analgesic Needs Questionnaire
24 Verbal Rating Scale for Pain
25 Visual Analogue Scale for Pain
26 West Haven-Yale Multidimensional Pain Inventory
27 Wisconsin Brief Pain Questionnaire

### Dyspnea

28 Visual analogue scale for dyspnea (HVAS/ VVAS)
29 Numeric Rating Scale (NRS) for dyspnea or dyspnea numeric scale
30 Modified Borg Scale (mBORG)
31 Global shortness of breath question (Global SOB)
32 Faces scale (Faces)
33 Dyspnea Descriptor Questionnaire (heart failure); DDQ (heart failure)
34 Dyspnea Descriptor Questionnaire (COPD)
35 Dyspnea Assessment Questionnaire (DAQ)
36 Amyotrophic lateral sclerosis functional rating scale – revised, respiratory subscale (ALSFRS-R)
37 American Thoracic Society Division of Lung Diseases 1978 Dyspnea Scale (ATS-DLD-78)
38 Breathlessness, Cough and Sputum Scale (BCSS)
39 Chronic Heart Failure Questionnaire – dyspnea subscale (CHQ-D)
40 Cardiovascular Limitations and Symptoms Profile (CLASP)
41 Chronic Lung Disease Severity Index (CLD)
42 Chronic Respiratory Questionnaire – dyspnea subscale (CRQ-D, CRQ-SAI-D)
43 Chronic Respiratory Questionnaire Standardized dyspnea questions (CRQ-SAS-D, CRQ-IAS-D)
44 European Organization for Research and Treatment of Cancer Quality of Life Questionnaire Lung Cancer supplement, breathlessness subscale (EORTC-QLQ; LC13 breathlessness)
45 London Chest Activity of Daily Living Scale (LCADL)
46 Motor Neurone Disease Dyspnea Rating Scale (MDRS-D)
47 Medical Research Council Dyspnea Scale (MRC)
48 Oxygen cost diagram (OCD)
49 Pulmonary Functional Status and Dyspnea Questionnaire-modified (PFSDQ-M)
50 Rand Instrument: shortness of breath battery from the Medical History Questionnaire (Rand)
51 St George's Respiratory Questionnaire (activity subscale) (SGRO)
52 University of Cincinnati Dyspnea Questionnaire (UCDQ)
53 University of California San Diego Shortness of Breath Questionnaire (UCSD SOBQ)

### Fatigue

54 Epworth Sleepiness Scale (ESS)
55 Fatigue Questionnaire (FQ)
56 Fatigue Symptom Inventory (FSI)
57 Fatigue Severity Scale (FSS)
58 Multidimensional Fatigue Symptoms Inventory (MFSI)
59 Piper Fatigue Scale
60 Brief Fatigue Inventory

## Domain 3 Psychosocial and Psychiatric

61 WHO (Five) Well-Being Index
62 Geriatric Depression Scale (long and short form)
63 Hamilton Depression Scale
64 Scales of Psychological Well-Being
65 Center for Epidemiologic Studies Depression Scale (CES-D)
66 Impact of Event Scale (IES)
67 Mental Health Inventory
68 Pain Anxiety Symptoms Scale (PASS)
69 Profile of Mood States
70 Present State Examination (PSE)
71 Reactions to the Diagnosis of Cancer Questionnaire (RDCQ)
72 Self-rating Depression Scale
73 The Symptom Questionnaire (SQ)
74 State-Trait Anxiety Inventory (STAI)
75 Starck Scale
76 Symptom Anxiety and Depression Scale
77 Cornell Scale for Depression in Dementia
78 PRIME-MD / PHQ-9
79 Hospital Anxiety and Depression Scale (HADS)
80 Two single items: Are you depressed? and Have you lost interest?
81 Distress Thermometer
82 Brief Symptom Inventory-18
83 General Health Questionnaire-12 item (GHQ-12 )
84 Brief Edinburgh Depression Scale
85 Beck Depression Inventory-Short Form
86 Mental Adjustment to Cancer

## Domain 4 Social (Caregiving)

87 Caregiver's Burden Scale in end-of-life care (CBS-EOLC)
88 Caregiver Impact Scale (CIS)
89 Caregiver Quality of Life Index – Cancer (CQOLI-C)
90 Caregiver Reaction Assessment (CRA)
91 Caregiver Strain Index (CSI)
92 Family Appraisal of Caregiving Questionnaire for Palliative Care (FACQ-PC)
93 Quality of Life in Life-Threatening Illness-Family Career Version (QOLLTI-F)
94 Zarit Burden Inventory (ZBI)

## Domain 5 Spiritual, Religious, and Existential

95 Beck Hopelessness Scale (BHS)
96 Ironson-Woods Spirituality/Religiousness Index (I-W SR Index Short Form)

## Domain 6 Cultural

—No tools were found for this domain.—

## Domain 7 Care at the End of Life (Bereavement)

97 Bereavement Experience Questionnaire–24 (BEQ-24)
98 Brief Grief Questionnaire (BGQ)
99 Core Bereavement Items (CBI)
100 Grief Evaluation Measure (GEM)
101 Grief Experience Questionnaire (GEQ)
102 Hogan Grief Reaction Checklist (HGRC)
103 Inventory of Complicated Grief (ICG)
104 Inventory of Complicated Grief–Revised (ICG-R)
105 Inventory of Traumatic Grief (ITG)
106 Marwit–Meuser Caregiver Grief Inventory (MMCGI)
107 Marwit–Meuser Caregiver Grief Inventory–Short Form (MM-CGI-SF)
108 Prolonged Grief–12 (PG-12)
109 Prolonged Grief–13 (PG-13)
110 Revised Grief Experience Inventory (R-GEI)
111 Texas Revised Inventory of Grief (TRIG)
112 Two-Track Bereavement Questionnaire (TTBQ)
113 Two-Track Bereavement Questionnaire (TTBQ2-CG30)

## Domain 8 Ethical and Legal

114 Relatives' patient management questionnaire
115 Willingness to Accept Life- sustaining Treatment instrument (WALT)

## Multidimensional Tools

### Quality of Life

116 Brief Hospice Inventory (BHI)
117 Cambridge Palliative Audit Schedule (CAMPAS-R)
118 Demoralization Scale (DS)
119 Edmonton Functional Assessment Tool (EFAT and EFAT-2)
120 Emanuel and Emanuel Medical Directive
121 European Organization for Research and Treatment of Cancer Quality of Life Questionnaire – Oesophageal cancer module (EORTC QLQ-OESI8)
122 European Organization for Research and Treatment of Cancer Quality of Life Questionnaire – Gastric cancer module (EORTC QLQ-ST022)
123 Edmonton Symptom Assessment Scale (ESAS)
124 Functional Assessment of Chronic Illness Therapy-Palliative sub scale (FACIT-Pal)
125 Hospice Quality of Life Index (HQLI)
126 Life Closure Scale (LCS)
127 Life Evaluation Questionnaire (LEQ)
128 McMaster Quality of Life Scale (MQLS)
129 McGill Quality of Life Questionnaire (MQOL)
130 McGill Quality of Life Questionnaire-Cardiff Short Form (MQOL-CSF)
131 McCanse Readiness for Death Instrument (MRDI)
132 Memorial Symptom Assessment Scale (MSAS)
133 Condensed Memorial Symptom Assessment Scale (CMSAS)
134 Memorial Symptom Assessment Scale-Global Distress Index (MSAS-GDI)
135 Missoula-VITAS Quality of Life Index (MVQOLI-R)
136 Needs Assessment for Advanced Cancer Patients (NA-ACP)
137 Patient Autonomy Questionnaire (PAQ)
138 Patient Dignity Inventory (PDI)
139 Problems and Needs in Palliative Care questionnaire (PNPC)
140 Problems and Needs in Palliative Care questionnaire-short version (PNPC-sv)
141 Palliative care Outcome Scale (POS)
142 Quality of life at the end of life (QUAL-E)
143 Spiritual Needs Inventory (SNI)

### Patient Experience

144 After Death Bereaved Family Member Interview
145 End of Life in Dementia- Satisfaction with Care & Comfort Assessment in Dying
146 Family Assessment of Treatment of End-of-Life survey
147 Family Evaluation of Hospice Care
148 Family Satisfaction in the ICU
149 Family Satisfaction with Advanced Cancer Care (FAMCARE)
150 Quality of Dying and Death
151 Quality of End-of-Life Care and Satisfaction with Treatment
152 Caregiver Evaluation of Quality of End-of-Life Care