# Appendix H Results of the Literature Search

Figure H-1 Results of the main literature search to identify relevant systematic reviews

^*^ Information for this domain obtained from an unpublished systematic review.

Appendix Figure H-1 represents the results of the systematic literature search where we searched 3 databases: PubMed, Cochrane, and CINAHL, and conducted a hand search identifying a total of 397 unique citations. Of these 54 were eligible for inclusion in this review, and ultimately 9 were chosen to provide information on the National Consensus Project Clinical Practice Guidelines domains.

Figure H-2 Results of the additional literature search to identify primary articles assessing palliative care tools in the cultural domain

Appendix Figure H-2 represents the results of the systematic literature search where we searched for primary articles addressing the culture domain. We searched PubMed and identified a total of 1372 unique citations. Of these none were eligible for inclusion in this review.