# Appendix G Inclusion Criteria for the Systematic Review

| Criteria
Content | Evaluates palliative care assessment tools used in palliative care in the areas of (1) clinical practice, (2) quality indicators, (3) evaluation of interventions
Population | Tools developed, evaluated, or implemented in populations defined as palliative care or meeting the definition of palliative care (care that provides relief from pain and other symptoms, supports quality of life, and is focused on patients with serious advanced illness and their families^1^) All diseases, age groups, and settings
Study Design | Systematic reviews For interventions, include systematic reviews of prospective controlled trials
Language/Country | English (for reviews)/United States (for tools)– since palliative care and use of assessment tools varies widely among countries, we focused on assessment tools used in US populations
Admissible Evidence | From published original studies: reliability, validity, and responsiveness (as summarized in reviews or websites)