# Appendix F Systematic Review and Supplemental Search Flow

^*^ TIME Toolkit of Instruments to Measure End-of-Life Care; National Institutes of Health State of the Science Conference on Improving End-of-Life Care; PEACE Palliative Care Quality Measures project

Appendix F illustrates the search flow. Eight domains defined by the National Consensus Project Clinical Practice Guidelines: Structure/Process of Care; Physical Aspects of Care; Psychological and Psychiatric Aspects of Care; Social Aspects of Care, Spiritual, Religious, and Existential Aspects of Care; Cultural Aspects of Care; Care of the Patient at the End of Life; Ethical and Legal Aspects of Care; and one additional domain called Tools that Cross Domains were sought in the search. If we were unable to identify any systematic reviews for any of these domains, we conducted a grey literature search. If this search did not identify tools for the domain not identified in a systematic review we conducted a targeted search of the primary literature.