# Appendix E ROBIS Assessment

Table E-1 Summary of ROBIS assessments

| Author, year | Domain 1: Study eligibility criteria | Domain 2: Identification and selection of studies | Domain 3: Data collection and study appraisal | Domain 4: Synthesis and findings | Risk of Bias in the Review
Physical (N=8)
| Allsop, 2015^1^ | Low | Unclear | Unclear | Unclear | Unclear
| Ben-Aharon, 2008^2^ | Low | Low | High | Unclear | Unclear
| Dorman, 2007^*,3^ | Low | Low | Unclear | Low | Low
| Gilbertson-White, 2011^4^ | High | High | High | High. | High
| Hjermstad, 2008^5^ | Low | High | High | Unclear | High
| Minton, 2009^6^ | Low | Low | High | Unclear | Unclear
| Seyidova-Khoshknabi, 2011^7^ | Low | Unclear | High | Unclear | Unclear
| Tomlinson, 2013 ^8^ | Low | Unclear | High | Unclear | Unclear
Psychosocial and Psychiatric (N=10)
| Hosie, 2013^9^ | High | Unclear | Unclear | Unclear | Unclear
| Kayser, 2012^10^ | Low | Low | Unclear | Unclear | Unclear
| Leonard, 2014^11^ | High | High | Unclear | Unclear | High
| Luckett, 2010^12^ | Low | Unclear | Unclear | Low | Unclear
| Mitchell, 2010^13^ | Low | Unclear | Unclear | Low | Unclear
| Mitchell, 2012^14^ | Low | Low | Unclear | Unclear | Unclear
| Thekkumpurath, 2008^15^ | Low | Unclear | High | Low | High
| Vodermaier, 2009^16^ | Low | Low | High | Low | High
| Wakefield, 2015^17^ | Low | Low | Low | Low | Low
| Ziegler, 2011^*,18^ | Low | Low | Low | Low | Low
Social (N=2)
| Hudson, 2010^19^ | Low | Low | Unclear | Unclear | Low
| Michels, 2016^*,20^ | Low | Low | Low | Unclear | Low
Spiritual, Religious, and Existential (N= 7)
| Best, 2015^21^ | Low | Low | Unclear | Low | Low
| Brandstatter, 2012^22^ | High | Unclear | Unclear | Unclear | High
| Gijsberts, 2011^23^ | High | Unclear | Unclear | Unclear | Unclear
| Harding, 2012^24^ | Unclear | Unclear | Unclear | Unclear | Unclear
| Krikorian, 2013^25^ | Low | Low | Unclear | Low | Low
| Selman, 2011^*,26^ | Low | Low | Low | Low | Low
| Selman, 2011^27^ | Low | Low | Low | Low | Low
Care of the Patient at the End of Life (Bereavement) (N=1)
| Sealey, 2015^*,28^ | Unclear | Low | Low | Low | Low
Multidimensional (Quality of life and Patient Experience) ((N=11)
(Quality of life) | Albers, 2010^*,29^ | Low | Low | Low | Unclear | Low
| Bausewein, 2011^30^ | Low | Low | High | Unclear | Unclear
| Coombes, 2016 ^31 2106^ | Low | Unclear | Unclear | Unclear | Unclear
| Chiu, 2014^32^ | Unclear | High | High | Unclear | High
| Hermans, 2014^33^ | Low | Low | Low | Unclear | Unclear
| Jordhoy, 2007^34^ | Unclear | Unclear | Unclear | Unclear | High
(Patient experience) | Lendon, 2015^*,35^ | Low | Low | Unclear | Low | Low
(Quality of life) | Paiva, 2014^36^ | Low | Low | Low | Unclear | Unclear
| Parker, 2011^37^ | Unclear | Low | Unclear | Unclear | Unclear
| Pearson, 2007^38^ | Low | High | High | High | High
| Stiel, 2012^39^ | Low | Unclear | Unclear | Unclear | Unclear
Prior comprehensive systematic reviews (N=1)
| Mularski, 2007^*,40^ | Low | Low | Unclear | Unclear | Unclear
Reviews of Clinical Care Tools (N=2)
| Antunes, 2014^*,41^ | Low | Low | Unclear | Low | Low
| Wasteson, 2009^42^ | Low | High | Unclear | Unclear | Unclear
Reviews of Quality Indicators (N=3)
| Bausewein, 2011^30^ | Low | Low | High | Unclear | Unclear
| De Roo, 2013^*,43^ | Low | Low | Unclear | Unclear | Low
| Pasman, 2009^44^ | Low | Low | Unclear | Unclear | Unclear
Reviews of Interventions (N=1)
| Kavalieratos, 2016^*,†,45^ | Low | Low | Low | Unclear | Low

N=sample size

* Systematic review included in the report.

† Unpublished article—ROBIS was conducted on the PROSPERO publically available protocol.

## References

1 Allsop MJ, Taylor S, Mulvey MR, . Information and communication technology for managing pain in palliative care: a review of the literature. BMJ Support Palliat Care. 2015 Dec;5(5):481-9. doi: 10.1136/bmjspcare-2013-000625. PMID: 24644214.24644214
2 Ben-Aharon I, Gafter-Gvili A, Paul M, . Interventions for alleviating cancer-related dyspnea: a systematic review. J Clin Oncol. 2008 May 10;26(14):2396-404. doi: 10.1200/jco.2007.15.5796. PMID: 18467732.18467732
3 Dorman S, Byrne A, Edwards A. Which measurement scales should we use to measure breathlessness in palliative care? A systematic review. Palliat Med. 2007 Apr;21(3):177-91. doi: 10.1177/0269216307076398. PMID: 17363394.17363394
4 Gilbertson-White S, Aouizerat BE, Jahan T, . A review of the literature on multiple symptoms, their predictors, and associated outcomes in patients with advanced cancer. Palliat Support Care. 2011 Mar;9(1):81-102. doi: 10.1017/s147895151000057x. PMID: 21352621.21352621
5 Hjermstad MJ, Gibbins J, Haugen DF, . Pain assessment tools in palliative care: an urgent need for consensus. Palliat Med. 2008 Dec;22(8):895-903. doi: 10.1177/0269216308095701. PMID: 18799513.18799513
6 Minton O, Stone P. A systematic review of the scales used for the measurement of cancer-related fatigue (CRF). Ann Oncol. 2009 Jan;20(1): 17-25. doi: 10.1093/annonc/mdn537. PMID: 18678767.18678767
7 Seyidova-Khoshknabi D, Davis MP, Walsh D. Review article: a systematic review of cancer-related fatigue measurement questionnaires. Am J Hosp Palliat Care. 2011 Mar;28(2): 119-29. doi: 10.1177/1049909110381590. PMID: 21051784.21051784
8 Tomlinson D, Hinds PS, Ethier MC, . Psychometric properties of instruments used to measure fatigue in children and adolescents with cancer: a systematic review. J Pain Symptom Manage. 2013 Jan;45(1):83-91. doi: 10.1016/j.jpainsymman.2012.02.010. PMID: 22889860.22889860
9 Hosie A, Davidson PM, Agar M, . Delirium prevalence, incidence, and implications for screening in specialist palliative care inpatient settings: a systematic review. Palliat Med. 2013 Jun;27(6):486-98. doi: 10.1177/0269216312457214. PMID: 22988044.22988044
10 Kayser K, Acquati C, Tran TV. No patients left behind: a systematic review of the cultural equivalence of distress screening instruments. J Psychosoc Oncol. 2012;30(6):679-93. doi: 10.1080/07347332.2012.721489. PMID: 23101551.23101551
11 Leonard MM, Nekolaichuk C, Meagher DJ, . Practical assessment of delirium in palliative care. Journal of Pain & Symptom Management. 2014;48(2): 176-90 15p. doi: 10.1016/j.jpainsymman.2013.10.024. PMID: 103839530. Language: English. Entry Date: 20150424. Revision Date: 20150710. Publication Type: Journal Article.
12 Luckett T, Butow PN, King MT, . A review and recommendations for optimal outcome measures of anxiety, depression and general distress in studies evaluating psychosocial interventions for English-speaking adults with heterogeneous cancer diagnoses. Support Care Cancer. 2010 Oct;18(10):1241-62. doi: 10.1007/s00520-010-0932-8. PMID: 20596731.20596731
13 Mitchell AJ. Short screening tools for cancer-related distress: a review and diagnostic validity meta-analysis. J Natl Compr Canc Netw. 2010 Apr;8(4):487-94. PMID: 20410338.20410338
14 Mitchell AJ, Meader N, Davies E, . Meta-analysis of screening and case finding tools for depression in cancer: evidence based recommendations for clinical practice on behalf of the Depression in Cancer Care consensus group. J Affect Disord. 2012 Oct;140(2):149-60. doi: 10.1016/j.jad.2011.12.043. PMID: 22633127.22633127
15 Thekkumpurath P, Venkateswaran C, Kumar M, . Screening for psychological distress in palliative care: a systematic review. J Pain Symptom Manage. 2008 Nov;36(5):520-8. doi: 10.1016/j.jpainsymman.2007.11.010. PMID: 18495416.18495416
16 Vodermaier A, Linden W, Siu C. Screening for emotional distress in cancer patients: a systematic review of assessment instruments. J Natl Cancer Inst. 2009 Nov 4;101(21):1464-88. doi: 10.1093/jnci/djp336. PMID: 19826136.19826136
17 Wakefield CE, Butow PN, Aaronson NA, . Patient-reported depression measures in cancer: a meta-review. Lancet Psychiatry. 2015 Jul;2(7):635-47. doi: 10.1016/s2215-0366(15)00168-6. PMID: 26303561.26303561
18 Ziegler L, Hill K, Neilly L, . Identifying psychological distress at key stages of the cancer illness trajectory: a systematic review of validated self-report measures. J Pain Symptom Manage. 2011 Mar;41(3):619-36. doi: 10.1016/j.jpainsymman.2010.06.024. PMID: 21310585.21310585
19 Hudson PL, Trauer T, Graham S, . A systematic review of instruments related to family caregivers of palliative care patients. Palliat Med. 2010 Oct;24(7):656-68. doi: 10.1177/0269216310373167. PMID: 20605852.20605852
20 Michels CT, Boulton M, Adams A, . Psychometric properties of carer-reported outcome measures in palliative care: A systematic review. Palliat Med. 2016 Jan;30(1):23-44. doi: 10.1177/0269216315601930. PMID: 26407683.26407683
21 Best M, Aldridge L, Butow P, . Assessment of spiritual suffering in the cancer context: A systematic literature review. Palliat Support Care. 2015 Oct;13(5): 1335-61. doi: 10.1017/s1478951514001217. PMID: 25386699.25386699
22 Brandstatter M, Baumann U, Borasio GD, . Systematic review of meaning in life assessment instruments. Psychooncology. 2012 Oct;21(10):1034-52. doi: 10.1002/pon.2113. PMID: 22232017.22232017
23 Gijsberts MJ, Echteld MA, van der Steen JT, . Spirituality at the end of life: conceptualization of measurable aspects-a systematic review. J Palliat Med. 2011 Jul;14(7):852-63. doi: 10.1089/jpm.2010.0356. PMID: 21612502.21612502
24 Harding R, List S, Epiphaniou E, . How can informal caregivers in cancer and palliative care be supported? An updated systematic literature review of interventions and their effectiveness. Palliat Med. 2012 Jan;26(1):7-22. doi: 10.1177/0269216311409613. PMID: 21737481.21737481
25 Krikorian A, Limonero JT, Corey MT. Suffering assessment: a review of available instruments for use in palliative care. J Palliat Med. 2013 Feb;16(2): 130-42. doi: 10.1089/jpm.2012.0370. PMID: 23350831.23350831
26 Selman L, Siegert R, Harding R, . A psychometric evaluation of measures of spirituality validated in culturally diverse palliative care populations. J Pain Symptom Manage. 2011 Oct;42(4):604-22. doi: 10.1016/j.jpainsymman.2011.01.015. PMID: 21640549.21640549
27 Selman L, Harding R, Gysels M, . The measurement of spirituality in palliative care and the content of tools validated cross-culturally: a systematic review. J Pain Symptom Manage. 2011 Apr;41(4):728-53. doi: 10.1016/j.jpainsymman.2010.06.023. PMID: 21306866.21306866
28 Sealey M, Breen LJ, O'Connor M, . A scoping review of bereavement risk assessment measures: Implications for palliative care. Palliat Med. 2015 Jul;29(7):577-89. doi: 10.1177/0269216315576262. PMID: 25805738.25805738
29 Albers G, Echteld MA, de Vet HC, . Evaluation of quality-of-life measures for use in palliative care: a systematic review. Palliat Med. 2010 Jan;24(1): 17-37. doi: 10.1177/0269216309346593. PMID: 19843620.19843620
30 Bausewein C, Le Grice C, Simon S, . The use of two common palliative outcome measures in clinical care and research: a systematic review of POS and STAS. Palliat Med. 2011 Jun;25(4):304-13. doi: 10.1177/0269216310395984. PMID: 21464119.21464119
31 Coombes LH, Wiseman T, Lucas G, . Health-related quality-of-life outcome measures in paediatric palliative care: A systematic review of psychometric properties and feasibility of use. Palliat Med. 2016 May 31doi: 10.1177/0269216316649155. PMID: 27247087.27247087
32 Chiu L, Chiu N, Chow E, . Comparison of Three Shortened Questionnaires for Assessment of Quality of Life in Advanced Cancer. J Palliat Med. 2014;17(8):918-23 6p. doi: 10.1089/jpm.2014.0012. PMID: 103984190. Language: English. Entry Date: 20140807. Revision Date: 20150803. Publication Type: Journal Article.
33 Hermans K, De Almeida Mello J, Spruytte N, . A comparative analysis of comprehensive geriatric assessments for nursing home residents receiving palliative care: a systematic review. J Am Med Dir Assoc. 2014 Jul;15(7):467-76. doi: 10.1016/j.jamda.2014.01.002. PMID: 24569081.24569081
34 Jordhoy MS, Inger Ringdal G, Helbostad JL, . Assessing physical functioning: a systematic review of quality of life measures developed for use in palliative care. Palliat Med. 2007 Dec;21(8):673-82. doi: 10.1177/0269216307083386. PMID: 18073253.18073253
35 Lendon JP, Ahluwalia SC, Walling AM, . Measuring Experience With End-of-Life Care: A Systematic Literature Review. J Pain Symptom Manage. 2015 May;49(5):904-15 e1-3. doi: 10.1016/j.jpainsymman.2014.10.018. PMID: 25543110.25543110
36 Paiva CE, Barroso EM, Carneseca EC, . A critical analysis of test-retest reliability in instrument validation studies of cancer patients under palliative care: a systematic review. BMC Med Res Methodol. 2014;14:8. doi: 10.1186/1471-2288-14-8. PMID: 24447633.24447633
37 Parker D, Hodgkinson B. A comparison of palliative care outcome measures used to assess the quality of palliative care provided in long-term care facilities: a systematic review. Palliat Med. 2011 Jan;25(1):5-20. doi: 10.1177/0269216310378786. PMID: 20817748.20817748
38 Pearson EJ, Todd JG, Futcher JM. How can occupational therapists measure outcomes in palliative care? Palliat Med. 2007 Sep;21(6):477-85. doi: 10.1177/0269216307081941. PMID: 17846087.17846087
39 Stiel S, Pastrana T, Balzer C, . Outcome assessment instruments in palliative and hospice care--a review of the literature. Support Care Cancer. 2012 Nov;20(11):2879-93. doi: 10.1007/s00520-012-1415-x. PMID: 22410859.22410859
40 Mularski RA, Dy SM, Shugarman LR, . A systematic review of measures of end-of-life care and its outcomes. Health Serv Res. 2007 Oct;42(5): 1848-70. doi: 10.1111/j.1475-6773.2007.00721.x. PMID: 17850523.17850523
41 Antunes B, Harding R, Higginson IJ. Implementing patient-reported outcome measures in palliative care clinical practice: a systematic review of facilitators and barriers. Palliat Med. 2014 Feb;28(2):158-75. doi: 10.1177/0269216313491619. PMID: 23801463.23801463
42 Wasteson E, Brenne E, Higginson IJ, . Depression assessment and classification in palliative cancer patients: a systematic literature review. Palliat Med. 2009 Dec;23(8):739-53. doi: 10.1177/0269216309106978. PMID: 19825894.19825894
43 De Roo ML, Leemans K, Claessen SJ, . Quality indicators for palliative care: update of a systematic review. J Pain Symptom Manage. 2013 Oct;46(4):556-72. doi: 10.1016/j.jpainsymman.2012.09.013. PMID: 23809769.23809769
44 Pasman HR, Brandt HE, Deliens L, . Quality indicators for palliative care: a systematic review. J Pain Symptom Manage. 2009 Jul;38(1): 145-56. doi: 10.1016/j.jpainsymman.2008.07.008. PMID: 19615636.19615636
45 Kavalieratos D, Corbelli J, Zhang D, . Association Between Palliative Care and Patient and Caregiver Outcomes: A Systematic Review and Meta-analysis. 2016;316(20):2104-14. doi: 10.1001/jama.2016.16840. PMID: 27893131.27893131