# Appendix D Detailed Search Strategy

Table D-1 PubMed search limited to systematic reviews and meta-analyses and published in 2007 or later

Database | Search
PubMed | ((“palliative care”[mh] OR “palliative care”[tiab] OR “end of life”[tiab] OR “hospice care”[mh] OR “terminally ill”[tiab] OR “terminal care”[tiab] OR “terminal illness”[tiab] OR Hospice[tiab]) AND (“assessment tool”[tiab] OR “assessment tools”[tiab] OR “Surveys and questionnaires”[Mesh] OR “Questionnaires”[tiab] OR “Questionnaire”[tiab] OR “self report”[tiab] OR instrument[tiab] OR instruments[tiab] OR scale[tiab] OR scales[tiab] OR instrumentation[tiab] OR “Psychometrics”[Mesh] OR “Psychometrics”[tiab] OR “Psychometric”[tiab]))

Table D-2 The Cochrane Library search strategy limited to systematic reviews and meta-analyses and published in 2007 or later

Cochrane | #1 | MeSH descriptor: [Palliative Care] explode all trees
Cochrane | #2 | MeSH descriptor: [Hospice Care] explode all trees
Cochrane | #3 | “palliative care”:ti,ab,kw (Word variations have been searched)
Cochrane | #4 | “terminally ill”:ti,ab,kw (Word variations have been searched)
Cochrane | #5 | “terminal care”:ti,ab,kw (Word variations have been searched)
Cochrane | #6 | “terminal illness”:ti,ab,kw (Word variations have been searched)
Cochrane | #8 | hospice:ti,ab,kw (Word variations have been searched)
Cochrane | #9 | MeSH descriptor: [Terminal Care] explode all trees
Cochrane | #10 | #1 or #2 or #3 or #4 or #5 or #6 or #8or #9
Cochrane | #11 | MeSH descriptor: [Surveys and Questionnaires] explode all trees
Cochrane | #12 | MeSH descriptor: [Psychometrics] explode all trees
Cochrane | #13 | “assessment tool”:ti,ab,kw (Word variations have been searched)
Cochrane | #14 | “assessment tools”:ti,ab,kw (Word variations have been searched)
Cochrane | #15 | Questionnaires:ti,ab,kw (Word variations have been searched)
Cochrane | #16 | Questionnaire:ti,ab,kw (Word variations have been searched)
Cochrane | #17 | “self report”:ti,ab,kw (Word variations have been searched)
Cochrane | #18 | instrument:ti,ab,kw (Word variations have been searched)
Cochrane | #19 | instruments:ti,ab,kw (Word variations have been searched)
Cochrane | #20 | scale:ti,ab,kw (Word variations have been searched)
Cochrane | #21 | scales:ti,ab,kw (Word variations have been searched)
Cochrane | #22 | instrumentation:ti,ab,kw (Word variations have been searched)
Cochrane | #23 | Psychometrics:ti,ab,kw (Word variations have been searched)
Cochrane | #24 | Psychometric:ti,ab,kw (Word variations have been searched)
Cochrane | #25 | #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23 or #24
Cochrane | | #10 and #25

Table D-3 CINAHL search strategy limited to systematic reviews and meta-analyses and published in 2007 or later

CINAHL/PsycINFO/PsycTESTS | S16 AND S44
CINAHL/PsycINFO/PsycTESTS | S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37 OR S38 OR S39 OR S40 OR S41 OR S42 OR S43
CINAHL/PsycINFO/PsycTESTS | AB “psychometrics”
CINAHL/PsycINFO/PsycTESTS | TI “psychometrics”
CINAHL/PsycINFO/PsycTESTS | AB “psychometric”
CINAHL/PsycINFO/PsycTESTS | TI “psychometric”
CINAHL/PsycINFO/PsycTESTS | AB “scales”
CINAHL/PsycINFO/PsycTESTS | TI “scales”
CINAHL/PsycINFO/PsycTESTS | AB “scale”
CINAHL/PsycINFO/PsycTESTS | TI “scale”
CINAHL/PsycINFO/PsycTESTS | AB “instrumentation”
CINAHL/PsycINFO/PsycTESTS | TI “instrumentation”
CINAHL/PsycINFO/PsycTESTS | AB “instruments”
CINAHL/PsycINFO/PsycTESTS | TI “instruments”
CINAHL/PsycINFO/PsycTESTS | AB “instrument”
CINAHL/PsycINFO/PsycTESTS | TI “instrument”
CINAHL/PsycINFO/PsycTESTS | AB “self report”
CINAHL/PsycINFO/PsycTESTS | TI “self report”
CINAHL/PsycINFO/PsycTESTS | AB “questionnaires”
CINAHL/PsycINFO/PsycTESTS | TI “questionnaires”
CINAHL/PsycINFO/PsycTESTS | AB “questionnaire”
CINAHL/PsycINFO/PsycTESTS | TI “questionnaire”
CINAHL/PsycINFO/PsycTESTS | AB “assessment tools”
CINAHL/PsycINFO/PsycTESTS | TI “assessment tools”
CINAHL/PsycINFO/PsycTESTS | AB “assessment tool”
CINAHL/PsycINFO/PsycTESTS | TI “assessment tool”
CINAHL/PsycINFO/PsycTESTS | MH “psychometrics”
CINAHL/PsycINFO/PsycTESTS | MH “self report”
CINAHL/PsycINFO/PsycTESTS | MH Questionnaires
CINAHL/PsycINFO/PsycTESTS | S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15
CINAHL/PsycINFO/PsycTESTS | AB “terminal care”
CINAHL/PsycINFO/PsycTESTS | TI “terminal care”
CINAHL/PsycINFO/PsycTESTS | AB “terminal illness”
CINAHL/PsycINFO/PsycTESTS | TI “terminal illness”
CINAHL/PsycINFO/PsycTESTS | AB “terminally ill”
CINAHL/PsycINFO/PsycTESTS | TI “terminally ill”
CINAHL/PsycINFO/PsycTESTS | AB “hospice”
CINAHL/PsycINFO/PsycTESTS | TI “hospice”
CINAHL/PsycINFO/PsycTESTS | AB “end of life”
CINAHL/PsycINFO/PsycTESTS | TI “end of life”
CINAHL/PsycINFO/PsycTESTS | AB “palliative care”
CINAHL/PsycINFO/PsycTESTS | TI “palliative care”
CINAHL/PsycINFO/PsycTESTS | MH “terminal care”
CINAHL/PsycINFO/PsycTESTS | MH “hospice care”
CINAHL/PsycINFO/PsycTESTS | MH “palliative care”

Table D-4 PubMed search limited to primary studies addressing culture and published in 2007 or later

# | Search
1 | “palliative care”[mh] OR “palliative care”[tiab] OR “end of life”[tiab] OR “hospice care”[mh] OR “terminally ill”[tiab] OR “terminal care”[tiab] OR “terminal illness”[tiab] OR Hospice[tiab])
2 | (“assessment tool”[tiab] OR “assessment tools”[tiab] OR “Surveys and questionnaires”[Mesh] OR “Questionnaires”[tiab] OR “Questionnaire”[tiab] OR “self report”[tiab] OR instrument[tiab] OR instruments[tiab] OR scale[tiab] OR scales[tiab] OR instrumentation[tiab] OR “Psychometrics”[Mesh] OR “Psychometrics”[tiab] OR “Psychometric”[tiab])
3 | ulture[mh] OR Culture[tiab] OR Cultural[tiab] OR Linguistics[mh] OR Linguistics[tiab] OR Linguistic[tiab] OR Language[mh] OR Language[tiab] OR Languages[tiab] OR “Family communication”[tiab] OR Customs[tiab] OR Custom[tiab] OR Beliefs[tiab] OR Values[tiab] OR Race[tiab] OR Ethnicity[tiab] OR “Social groups”[tiab] OR Truth telling[tiab])
| 1 AND 2 AND 3