# Appendix C Key Informant Questions

## Questions for Patient Advocates

1. What are key elements of high quality palliative care from your perspective?
2. Have you ever as a caregiver (or has the person you were caring for) been asked to fill out or asked questions from an assessment tool or survey, such as ratings of symptoms or a questionnaire about your experience with palliative care?
  If yes:
  - Were the questions meaningful?
  - Did the questions lead to a better experience?
  If no:
  - Why?
3. Based on your experiences, what do doctors and palliative care staff need to know from the patient or caregiver that can be captured in a questionnaire or similar tool?
4. Are there key things missing from the domains below that patients/ caregivers should be asked about?
5. Based on your experiences, do you have any other thoughts about how these tools or surveys should or should not be used in palliative care?

These are the domains:

1. Structure/Process of care (e.g., continuity, communication)
2. Physical Aspects of Care (e.g., pain, dyspnea)
3. Psychological and Psychiatric Aspects of Care
4. Social Aspects of Care (including caregiving)
5. Spiritual, Religious and Existential Aspects of Care
6. Cultural Aspects of Care (including cultural competence)
7. Care of the Patient at the End of Life
8. Ethical and Legal Aspects of Care (care planning)
9. Tools that cross domains (patient experience/satisfaction, comprehensive assessment)

## Questions for Providers

We are organizing assessment tools by domains from the National Consensus Project Clinical Practice Guidelines for Quality Palliative Care, which are:

1. Structure/Process of care (e.g., continuity, communication)
2. Physical Aspects of Care (e.g., pain, dyspnea)
3. Psychological and Psychiatric Aspects of Care
4. Social Aspects of Care (including caregiving)
5. Spiritual, Religious and Existential Aspects of Care
6. Cultural Aspects of Care (including cultural competence)
7. Care of the Patient at the End of Life
8. Ethical and Legal Aspects of Care (care planning)
9. Tools that cross domains (patient experience/satisfaction, comprehensive assessment)

1. Are these categories still valid, or do they need to be changed?
2. Based on your experiences and perceptions:
  a. What are key general issues with use of assessment tools in palliative care? (We are not looking for comments on specific tools, but rather on overall issues such as standardization, burden, unintended consequences, etc.).
  b. What are your experiences and perceptions about palliative care assessment tools that are used for:
    - clinical care delivery?
    - quality indicators?
    - evaluating the effectiveness of interventions?
3. How do you think tools should be evaluated? For example: validity, reliability, responsiveness and what should be the standard to consider a tool “good”?
4. How have the drawbacks of existing tools or lack of available tools affected the field of
  - palliative care for:
  - clinical care delivery?
  - quality indicators?
  - evaluating the effectiveness of interventions?
5. In addition to the list attached, are there any other databases or sources that we should search for studies about palliative care assessment tools?
6. Are there any specific issues you would like to bring up about assessment tools specifically for any of the domains (as above, [underlined: not for specific tools] but for the domain as a whole)?
  - structures and processes of care (e.g., continuity, communication):
  - physical aspects of care (e.g., pain, dyspnea, fatigue, nausea, anorexia, diarrhea, constipation):
  - the domain of psychological and psychiatric care:
  - social aspects of care, including caregiving:
  - spiritual, religious, and existential aspects of care (e.g., spiritual distress):
  - cultural aspects of care, including cultural competence:
  - end-of-life care:
  - ethical and legal aspects of care (e.g., care planning):
  - tools that cross multiple domains (e.g.., satisfaction, comprehensive assessment)
7. Are there key research gaps regarding palliative care assessment tools?