# Appendix B List of Acronyms

Table B-1 List of acronyms
Acronym: Definition
AHRQ: Agency for Healthcare Research and Quality
AIDS: Acquired Immune Deficiency Syndrome
ALSFRS-R: Amyotrophic lateral sclerosis functional rating scale
ATS-DLD-78: American Thoracic Society Division of Lung Diseases 1978 Dyspnea Scale
BCOS: Bakas Caregiving Outcomes Scale
BCSS: Breathlessness, Cough and Sputum Scale
BDI: Beck Depression Inventory
BEQ-24: Bereavement Experience Questionnaire–24
BGQ: Brief Grief Questionnaire
BHI: Brief Hospice Inventory
BHS: Beck Hopelessness Scale
BIC: Burden Index of Caregivers
CAMPAS-R: Cambridge Palliative Audit Schedule
CARES-MIS: Cancer Rehabilitation Evaluation System Medical Interaction Subscale
CBI: Core Bereavement Items
CBS-EOLC: Caregiver's Burden Scale in end-of-life care
CES-D: Center for Epidemiologic Studies Depression scale
CHF: Congestive Heart Failure
CHQ: Chronic Heart Failure Questionnaire
CHQ-D: Chronic Heart Failure Questionnaire – Dyspnea Subscale
CI: Confidence Interval
CIS: Caregiver Impact Scale
CLASP: Cardiovascular Limitations and Symptoms Profile
CLD: Chronic Lung Disease Severity Index
CMSAS: Condensed Memorial Symptom Assessment Scale
COPD: Chronic obstructive pulmonary disease
CQOLI: Caregiver Quality of Life Index
CQOLI-C: Caregiver Quality of Life Index – Cancer
CQOLI-R: Caregiver Quality of Life Index – Revised
CRA: Caregiver Reaction Assessment
CRQ: Chronic Respiratory Questionnaire
CRQ-D: Chronic Respiratory Questionnaire – Dyspnea Subscale
CSDD: Cornell Scale for Depression in Dementia
CSI: Caregiver Strain Index
DAQ: Dyspnea Assessment Questionnaire
DDQ: Dyspnea Descriptor Questionnaire
DS: Demoralization Scale
EFAT and EFAT-2: Edmonton Functional Assessment Tool
EOLD: End of Life Dementia
EORTC QLQ-ST022: European Organization for Research and Treatment of Cancer Quality of Life Questionnaire – Oesophageal cancer module
EORTC-QLQ: European Organization for Research and Treatment of Cancer Quality of Life Questionnaire
EPC: Evidence-based Practice Center
EQ-5D: EuroQOL
ESAS: Edmonton Symptom Assessment Scale
Faces: Faces scale
FACIT: Functional Assessment of Chronic Illness Therapy
FACIT-Pal: Functional Assessment of Chronic Illness Therapy-Palliative sub scale
FACIT-L: Functional Assessment of Chronic Illness Therapy-Lung
FACQ-PC: Family Appraisal of Caregiving Questionnaire for Palliative Care
FAMCARE: Family Satisfaction with Advanced Cancer Care
GEM: Grief Evaluation Measure
GEQ: Grief Experience Questionnaire
GHQ-12: General Health Questionnaire-12 item
Global SOB: Global shortness of breath question
HADS: Hospital Anxiety and Depression Scale
HGRC: Hogan Grief Reaction Checklist
HIV: Human Immunodeficiency Virus
HQLI: Hospice Quality of Life Index
ICG: Inventory of Complicated Grief
ICG-R: Inventory of Complicated Grief–Revised
ICU: Intensive Care Unit
IES: Impact of Event Scale
IPC: Sat-Fam
ITG: Inventory of Traumatic Grief
ITU: Intensive Therapy Unit
I-W SR Index Short Form: Ironson-Woods Spirituality/Religiousness Index
KI: Key Informant
KQ: Key Question
LASA: Linear Analogue Scale Assessment
LC13: Lung Cancer supplement, breathlessness scale
LCADL: London Chest Activity of Daily Living Scale
LCS: Life Closure Scale
LEQ: Life Evaluation Questionnaire
MBCBS: Montgomery Borgatta Caregiver Burden Scale
mBORG: Modified Borg Scale
MCOHPQ: Modified City of Hope Patient Questionnaire
MDRS-D: Motor Neurone Disease Dyspnea Rating Scale
MMCGI: Marwit–Meuser Caregiver Grief Inventory
MND: Motor neuron disease
MOS: Medical Outcomes Study
MOS-HIV: Medical Outcomes Study HIV Health Survey
MPAC: Memorial Pain Assessment Card
MQLS: McMaster Quality of Life Scale
MQOL: McGill Quality of Life Questionnaire
MQOL-CSF: McGill Quality of Life Questionnaire-Cardiff Short Form
MRC: Medical Research Council Dyspnea Scale
MRDI: McCanse Readiness for Death Instrument
MSAS: Memorial Symptom Assessment Scale
MSAS-GDI: Memorial Symptom Assessment Scale-Global Distress Index
MVQOLI-R: Missoula-VITAS Quality of Life Index
N: Not present in the primary article
NA-ACP: Needs Assessment for Advanced Cancer Patients
NCP: National Consensus Project for Quality Palliative Care Clinical Practice
ND: No data available (review did not abstract)
NRS: Numeric rating scale
NS: Not Significant
OCD: Oxygen cost diagram
PAINAID: Pain in Advanced Dementia
PASS: Pain Anxiety Symptoms Scale
PAQ: Patient Autonomy Questionnaire
PDI: Patient Dignity Inventory
PEACE: “Prepare, Embrace, Attend, Communicate, Empower” project
PFSDQ-M: Pulmonary Functional Status and Dyspnea Questionnaire-modified
PG-12: Prolonged Grief–12
PG-13: Prolonged Grief–13
PHQ-9: Patient Health Questionnaire-9
PNPC: Problems and Needs in Palliative Care questionnaire
PNPCsv: Problems and Needs in Palliative Care questionnaire short version
POMS: Profile of Mood States
POS: Palliative care Outcome Scale
PRIME-MD: Primary Care Evaluation of Mental Disorders
PSE: Present State Examination
QODD: Quality of Dying and Death questionnaire
QOLLTI-F: Quality of Life in Life-Threatening Illness-Family Career Version
QUAL-E: Quality of Life at the end of life
RAND: Rand Instrument: Shortness of Breath Batter from the Medical History Questionnaire
RDCQ: Reactions to the Diagnosis of Cancer Questionnaire
R-GEI: Revised Grief Experience Inventory
ROBIS: Risk of Bias in Systematic Reviews
RSCD: Regional Study of Care for the Dying
SF-12: Short Form 12 Health Survey
SF-36: Short Form 36 Health Survey
SGRO: St George's Respiratory Questionnaire (activity subscale)
SMD: Standardized Mean Difference
SNI: Spiritual Needs Inventory
SQ: The Symptom Questionnaire
SS-SOBS: Symptom Scale (shortness of breath subscale)
STAI: State-Trait Anxiety Inventory
TIME: Toolkit of Instruments to Measure End-of-Life Care
TOI: Trial Outcome Index
TOO: Task Order Officer
TRIG: Texas Revised Inventory of Grief
TTBQ: Two-Track Bereavement Questionnaire
TTBQ2-CG30: Two-Track Bereavement Questionnaire
TQPM: Cancer Total Quality Pain Management Patient Assessment Tool
UCDQ: University of Cincinnati Dyspnea Questionnaire
UCSD SOBQ: University of California San Diego Shortness of Breath Questionnaire
VAS: Visual analogue scale
WALT: Willingness to Accept Life-Sustaining Treatment Instrument
WHO: World Health Organization
WONCA: World Organization of National Colleges, Academies and Academic Association of General Practitioners
Y: Present in the primary article
ZBI: Zarit Burden Inventory