# Appendix A Glossary

Adapted from: National Quality Forum. Patient Reported Outcomes (PROs) in Performance Measurement, 2013 and Guidance for Measure Testing and Evaluating Scientific Acceptability of Measure Properties, 2011. Qualityforum.org.

## Table A-1 Glossary of terms

Term: Definition/examples
1. Reliability: The degree to which an instrument is free from random error
1a. Internal consistency reliability (multi-item scales): Correlations between items on the same test
1b. Test-retest reliability (reproducibility or stability over time): Test-retest estimation at different times
1c. Inter-rater reliability: Degree of agreement among raters (e.g., patient vs proxy)
2. Validity (Focus on construct validity – associations with different measures): The degree to which an instrument reflects what it is supposed to measure
2a. Convergent validity: Documentation of empirical findings that support predefined hypotheses on the expected associations among measures similar to the measured patient reported measure
2b. Discriminant validity: Documentation that measures that are not supposed to be related are, in fact, unrelated
2c. Criterion validity: Extent to which a measure is related to an outcome. Can be concurrent (at the same time) or predictive (at a future time)
3. Sensitivity to change/ responsiveness: Empirical evidence of changes in scores consistent with predefined hypotheses regarding changes in the target population
4. Burden: Time, effort, and other demands on the respondent and administrator
4a. Number of items: Number of items; long and short form
4b. Modes of administration: Paper, web-based, interview
4c. Completion time (usability): Time for the respondent