# References

1 Heart Disease and Stroke Statistics—2009 Update (All Charts). American Heart Association. Available at: http://www.americanheart.org/presenter.jhtml?identifier=3018163. Accessed August 17, 2009.
2 World Health Organization, Cardiovascular Diseases Fact Sheet. Available at: http://www.who.int/mediacentre/factsheets/fs317/en/print.html. Accessed August 17, 2009.
3 Cannon CP, Braunwald E, McCabe CH, et al. Intensive versus moderate lipid lowering with statins after acute coronary syndromes. N Engl J Med. 2004;350:1495-1504. [pmid: 15007110].
4 Vulnerable Plaques. A Brief Review of the Concept and Proposed Approaches to Diagnosis and Treatment. Technology Assessment. January. 2004. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://www.ahrq.gov/clinic/ta/placque/.
5 Fourth International Conference on Grey Literature. Washington DC. 1999.
6 Waxman S, Ishibashi F, Muller JE. Detection and treatment of vulnerable plaques and vulnerable patients: novel approaches to prevention of coronary events. Circulation. 2006;114:2390-2411. [pmid: 17130356].
7 US Food and Drug Administation Premarket Notifications (510(k)s) Database. Available at: http://www.accessdata.fda.gov/scrIpts/cdrh/cfdocs/cfPMN/pmn.cfm. 2009.
8 Drugs@FDA Database. Available at: http://www.accessdata.fda.gov/Scripts/cder/DrugsatFDA/. 2009.
9 Muller JE, Tofler GH, Stone PH. Circadian variation and triggers of onset of acute cardiovascular disease. Circulation. 1989;79:733-743. [pmid: 2647318].
10 Ambrose JA, Winters SL, Arora RR, et al. Angiographic evolution of coronary artery morphology in unstable angina. J Am Coll Cardiol. 1986;7:472-478. [pmid: 3950227].
11 Little WC, Constantinescu M, Applegate RJ, et al. Can coronary angiography predict the site of a subsequent myocardial infarction in patients with mild-to-moderate coronary artery disease?. Circulation. 1988;78:1157-1166. [pmid: 3180375].
12 Hackett D, Davies G, Maseri A. Pre-existing coronary stenoses in patients with first myocardial infarction are not necessarily severe. Eur Heart J. 1988;9:1317-1323. [pmid: 3229426].
13 Giroud D, Li JM, Urban P, et al. Relation of the site of acute myocardial infarction to the most severe coronary arterial stenosis at prior angiography. Am J Cardiol. 1992;69:729-732. [pmid: 1546645].
14 Naqvi TZ, Hachamovitch R, Berman D, et al. Does the presence and site of myocardial ischemia on perfusion scintigraphy predict the occurrence and site of future myocardial infarction in patients with stable coronary artery disease?. Am J Cardiol. 1997;79:1521-1524. [pmid: 9185646].
15 Kolodgie FD, Virmani R, Burke AP, et al. Pathologic assessment of the vulnerable human coronary plaque. Heart. 2004;90:1385-1391. [pmid: 15547008].
16 Narula J, Garg P, Achenbach S, et al. Arithmetic of vulnerable plaques for noninvasive imaging. Nature Clinical Practice Cardiovascular Medicine. 2008;5.
17 Virmani R, Burke AP, Farb A, et al. Pathology of the vulnerable plaque. J Am Coll Cardiol. 2006;47:C13-C18. [pmid: 16631505].
18 Naghavi M, Libby P, Falk E, et al. From vulnerable plaque to vulnerable patient: a call for new definitions and risk assessment strategies: Part I. Circulation. 2003;108:1664-1672. [pmid: 14530185].
19 Virmani R, Kolodgie FD, Burke AP, et al. Lessons from sudden coronary death: a comprehensive morphological classification scheme for atherosclerotic lesions. Arterioscler Thromb Vasc Biol. 2000;20:1262-1275. [pmid: 10807742].
20 Kolodgie FD, Virmani R, Burke AP, et al. Pathologic assessment of the vulnerable human coronary plaque. Heart. 2004;90:1385-1391. [pmid: 15547008].
21 Motoyama S, Sarai M, Harigaya H, et al. Computed tomographic angiography characteristics of atherosclerotic plaques subsequently resulting in acute coronary syndrome. J Am Coll Cardiol. 2009;54:49-57. [pmid: 19555840].
22 Kim SH, Hong MK, Park DW, et al. Impact of plaque characteristics analyzed by intravascular ultrasound on long-term clinical outcomes. Am J Cardiol. 2009;103:1221-1226. [pmid: 19406263].
23 Lee SG, Lee CW, Hong MK, et al. Change of multiple complex coronary plaques in patients with acute myocardial infarction: a study with coronary angiography. Am Heart J. 2004;147:281-286. [pmid: 14760326].
24 Ohtani T, Ueda Y, Mizote I, et al. Number of yellow plaques detected in a coronary artery is associated with future risk of acute coronary syndrome: detection of vulnerable patients by angioscopy. J Am Coll Cardiol. 2006;47:2194-2200. [pmid: 16750684].
25 Bayturan O, Tuzcu EM, Nicholls SJ, et al. Attenuated plaque at nonculprit lesions in patients enrolled in intravascular ultrasound atherosclerosis progression trials. Jacc: Cardiovasc Interv. 2009;2:672-678. [pmid: 19628192].
26 Reiter M, Effenberger I, Sabeti S, et al. Increasing carotid plaque echolucency is predictive of cardiovascular events in high-risk patients. Radiology. 2008;248:1050-1055. [pmid: 18710994].
27 Hashimoto H, Tagaya M, Niki H, et al. Computer-assisted analysis of heterogeneity on B-mode imaging predicts instability of asymptomatic carotid plaque. Cerebrovasc Dis. 2009;28:357-364. [pmid: 19628937].
28 Brajovic MD, Markovic N, Loncar G, et al. The influence of various morphologic and hemodynamic carotid plaque characteristics on neurological events onset and deaths. Scientific World Journal. 2009;9:509-521. [pmid: 19578708].
29 Takaya N, Yuan C, Chu B, et al. Association between carotid plaque characteristics and subsequent ischemic cerebrovascular events: a prospective assessment with MRI—initial results. Stroke. 2006;37:818-823. [pmid: 16469957].
30 Takaya N, Yuan C, Chu B, et al. Association between carotid plaque characteristics and subsequent ischemic cerebrovascular events: a prospective assessment with MRI—initial results. Stroke. 2006;37:818-823. [pmid: 16469957].
31 Takaya N, Yuan C, Chu B, et al. Presence of intraplaque hemorrhage stimulates progression of carotid atherosclerotic plaques: a high-resolution magnetic resonance imaging study. Circulation. 2005;111:2768-2775. [pmid: 15911695].
32 Underhill HR, Yuan C, Yarnykh VL, et al. Predictors of Surface Disruption with MR Imaging in Asymptomatic Carotid Artery Stenosis. AJNR Am J Neuroradiol. 2009.
33 Altaf N, MacSweeney ST, Gladman J, et al. Carotid intraplaque hemorrhage predicts recurrent symptoms in patients with high-grade carotid stenosis. Stroke. 2007;38:1633-1635. [pmid: 17379827].
34 Davies MJ. Pathology of arterial thrombosis. Br Med Bull. 1994;50:789-802. [pmid: 7804731].
35 Burke AP, Kolodgie FD, Farb A, et al. Healed plaque ruptures and sudden coronary death: evidence that subclinical rupture has a role in plaque progression. Circulation. 2001;103:934-940. [pmid: 11181466].
36 Altaf N, MacSweeney ST, Gladman J, et al. Carotid intraplaque hemorrhage predicts recurrent symptoms in patients with high-grade carotid stenosis. Stroke. 2007;38:1633-1635. [pmid: 17379827].
37 Barlis P, Serruys PW, Gonzalo N, et al. Assessment of culprit and remote coronary narrowings using optical coherence tomography with long-term outcomes. Am J Cardiol. 2008;102:391-395. [pmid: 18678293].
38 Gibson CM, Sandor T, Stone PH, et al. Quantitative angiographic and statistical methods to assess serial changes in coronary luminal diameter and implications for atherosclerosis regression trials. Am J Cardiol. 1992;69:1286-1290. [pmid: 1585861].
39 Panayiotou A, Griffin M, Georgiou N, et al. ApoB/ApoA1 ratio and subclinical atherosclerosis. Int Angiol. 2008;27:74-80. [pmid: 18277343].
40 Martin RM, Gunnell D, Whitley E, et al. Associations of insulin-like growth factor (IGF)-I, IGF-II, IGF binding protein (IGFBP)-2 and IGFBP-3 with ultrasound measures of atherosclerosis and plaque stability in an older adult population. J Clin Endocrinol Metab. 2008;93:1331-1338. [pmid: 18211967].
41 Serruys PW, Garcia-Garcia HM, Buszman P. Effects of the direct lipoprotein-associated phospholipase A(2) inhibitor darapladib on human coronary atherosclerotic plaque. Circulation. 2008;118:1172-1182. [pmid: 18765397].
42 Thies F, Garry JM, Yaqoob P, et al. Association of n-3 polyunsaturated fatty acids with stability of atherosclerotic plaques: a randomised controlled trial. Lancet. 2003;361:477-485. [pmid: 12583947].
43 Schmidt C, Fagerberg B, Wikstrand J, et al. Multiple risk factor intervention reduces cardiovascular risk in hypertensive patients with echolucent plaques in the carotid artery. J Intern Med. 2003;253:430-438. [pmid: 12653872].
44 Marfella R, D’Amico M, Di FC, et al. Increased activity of the ubiquitin-proteasome system in patients with symptomatic carotid disease is associated with enhanced inflammation and may destabilize the atherosclerotic plaque: effects of rosiglitazone treatment. J Am Coll Cardiol. 2006;47:2444-2455. [pmid: 16781372].
45 Okada K, Ueda Y, Oyabu J, et al. Plaque color analysis by the conventional yellow-color grading system and quantitative measurement using LCH color space. J Interv Cardiol. 2007;20:324-334. [pmid: 17880328].
46 Annovazzi A, Bonanno E, Arca M, et al. 99mTc-interleukin-2 scintigraphy for the in vivo imaging of vulnerable atherosclerotic plaques. Eur J Nucl Med Mol Imaging. 2006;33:117-126. [pmid: 16220305].
47 Nakamura T, Obata JE, Kitta Y, et al. Rapid stabilization of vulnerable carotid plaque within 1 month of pitavastatin treatment in patients with acute coronary syndrome. J Cardiovasc Pharmacol. 2008;51:365-371. [pmid: 18427279].
48 Watanabe K, Sugiyama S, Kugiyama K, et al. Stabilization of carotid atheroma assessed by quantitative ultrasound analysis in nonhypercholesterolemic patients with coronary artery disease. J Am Coll Cardiol. 2005;46:2022-2030. [pmid: 16325036].
49 Kadoglou NP, Gerasimidis T, Moumtzouoglou A, et al. Intensive lipid-lowering therapy ameliorates novel calcification markers and GSM score in patients with carotid stenosis. Eur J Vasc Endovasc Surg. 2008;35:661-668. [pmid: 18395477].
50 Kunte H, Amberger N, Busch MA, et al. Markers of instability in high-risk carotid plaques are reduced by statins. J Vasc Surg. 2008;47:513-522. [pmid: 18295103].
51 Koutouzis M, Nomikos A, Nikolidakis S, et al. Statin treated patients have reduced intraplaque angiogenesis in carotid endarterectomy specimens. Atherosclerosis. 2007;192:457-463. [pmid: 17335827].
52 Pucci A. In vivo coronary plaque histology in patients with stable and acute coronary syndromes: relationships with hyperlipidemic status and statin treatment. Atherosclerosis. 2007:189-195. [pmid: 16970947].
53 Hirano M, Nakamura T, Kitta Y, et al. Rapid improvement of carotid plaque echogenicity within 1 month of pioglitazone treatment in patients with acute coronary syndrome. Atherosclerosis. 2009;203:483-488. [pmid: 18757056].
54 Hirayama A, Saito S, Ueda Y, et al. Qualitative and quantitative changes in coronary plaque associated with atorvastatin therapy. Circulation Journal. 2009;73:718-725. [pmid: 19225206].
55 Takarada S, Imanishi T, Kubo T, et al. Effect of statin therapy on coronary fibrous-cap thickness in patients with acute coronary syndrome: assessment by optical coherence tomography study. Atherosclerosis. 2009;202:491-497. [pmid: 18572175].
56 Tang TY, Howarth SP, Miller SR, et al. The ATHEROMA (Atorvastatin Therapy: Effects on Reduction of Macrophage Activity) Study. Evaluation using ultrasmall superparamagnetic iron oxide-enhanced magnetic resonance imaging in carotid disease. Journal of the American College of Cardiology. 2009;53:2039-2050. [pmid: 19477353].
57 Yamada K, Yoshimura S, Kawasaki M, et al. Effects of atorvastatin on carotid atherosclerotic plaques: a randomized trial for quantitative tissue characterization of carotid atherosclerotic plaques with integrated backscatter ultrasound. Cerebrovasc Dis. 2009;28:417-424. [pmid: 19707015].
58 Koutouzis M, Nomikos A, Nikolidakis S, Tzavara V, Andrikopoulos V, Nikolaou N, et al. Statin treated patients have reduced intraplaque angiogenesis in carotid endarterectomy specimens. Atherosclerosis. 2007;192:457-463. [pmid: 17335827].
59 Tang TY, Howarth SP, Miller SR, et al. The ATHEROMA (Atorvastatin Therapy: Effects on Reduction of Macrophage Activity) Study. Evaluation using ultrasmall superparamagnetic iron oxide-enhanced magnetic resonance imaging in carotid disease. Journal of the American College of Cardiology. 2009;53:2039-2050. [pmid: 19477353].
60 Waxman S, Ishibashi F, Muller JE. Detection and treatment of vulnerable plaques and vulnerable patients: novel approaches to prevention of coronary events. Circulation. 2006;114:2390-2411. [pmid: 17130356].
61 Ramcharitar S, Gonzalo N, van Geuns RJ, et al. First case of stenting of a vulnerable plaque in the SECRITT I trial-the dawn of a new era?. Nature Reviews Cardiology. 2009;6:374-378.
62 Koutouzis M, Nomikos A, Nikolidakis S, et al. Statin treated patients have reduced intraplaque angiogenesis in carotid endarterectomy specimens. Atherosclerosis. 2007;192:457-463. [pmid: 17335827].
63 Tang TY, Howarth SP, Miller SR, et al. The ATHEROMA (Atorvastatin Therapy: Effects on Reduction of Macrophage Activity) Study. Evaluation using ultrasmall superparamagnetic iron oxide-enhanced magnetic resonance imaging in carotid disease. Journal of the American College of Cardiology. 2009;53:2039-2050. [pmid: 19477353].
64 Nissen SE, Wolski K. Effect of rosiglitazone on the risk of myocardial infarction and death from cardiovascular causes [Erratum appears in N Engl J Med 2007 Jul 5;357(1):100]. N Engl J Med. 2007;356:2457-2471. [pmid: 17517853].
65 Lincoff AM, Wolski K, Nicholls SJ, et al. Pioglitazone and risk of cardiovascular events in patients with type 2 diabetes mellitus: a meta-analysis of randomized trials. JAMA. 2007;298:1180-1188. [pmid: 17848652].
66 Nighoghossian N, Derex L, Douek P. The vulnerable carotid artery plaque: current imaging methods and new perspectives. Stroke. 2005;36:2764-2772. [pmid: 16282537].