# Methods

The objective of this report is to assess, with a systematic review approach, the volume and type of evidence available on vulnerable plaque. The purpose is to provide a basis for establishing how the research field is evolving and identify topics that may require further research. We created an “evidence map” that describes the tests that have been evaluated, the populations in which they have been evaluated, and the types of studies that have been used. This review is not a detailed technology assessment based on a systematic review of full-text articles. It does not synthesize or evaluate the results of individual clinical studies and does not make clinical recommendations. “Vulnerable plaque” is still an evolving concept and is not an established medical diagnosis. Therefore, any reference to “vulnerable plaque” in this report concerning its natural history, diagnostic methods, and treatments is by necessity inferential. It refers to conditions that might fall under the current concept of vulnerable plaque but not specifically about vulnerable plaque.

## Literature Search Strategy

We searched MEDLINE to identify English language publications on vulnerable plaque. Because it is an emerging concept, there are no specific medical subject headings (MeSH terms) available. Therefore, exclusively text words were used. The search terms included vulnerable plaque, unstable plaque, atheromatous plaque, ulcerative plaque, and related words. The search was limited to English language studies conducted in humans. Because we were updating our 2004 technical report and were focusing on the current thinking about the vulnerable plaque concept, we limited the search to the period from 2003 to April 2010. The search results were reviewed independently by four reviewers (AA, EB, GK and SI). All potentially relevant abstracts were re-screened by a cardiologist (AA).

In order to identify the available testing devices, imaging modalities and drugs that would be of interest to vulnerable plaque, a grey literature^a^ search approach5 was used to seek information on the corresponding biomarkers, imaging methods and therapeutic approaches identified by the systematic literature overview. The Google™ website and, specific companies’ websites were searched. For the Google search, topic related keywords were used. Given the non-specific nature of the Google search engine and the lack of a concrete definition of vulnerable plaque, a list of companies known to sponsor clinical trials related to the vulnerable plaque concept6 and a list of testing modalities and drugs identified from the systematic literature overview were created.

a According to the Fourth International Conference on Grey Literature in Washington, DC, in October 1999,^5^ grey literature was defined as: “That which is produced on all levels of government, academics, business and industry in print and electronic formats, but which is not controlled by commercial publishers.” Grey literature can include, but is not limited to reports, memoranda, conference proceedings, standards, technical documentation, government documents, and in this case also includes information retrieved from commercial manufacturer and distributor websites.

The products relating to the detection or treatment of plaques were researched within each company site, and relevant information was recorded. Following this, the testing modality keywords were entered into the Google search engine in an effort to identify other producers of related products. Some of the general keywords included: intravascular ultrasound-virtual histology; near-infrared spectroscopy; 320-multidetector computed tomography; angioscopy; Raman spectroscopy; optical coherence tomography; palpography-elastography; magnetic resonance imaging; and variations of these terms. After inspection, the most relevant and pertinent information relating to the keywords invariably appeared within the first three to five pages of the Google search results. Thus, search results on these relevant pages were relied upon in order to gather device information.

As the manufacturer and/or company websites varied in their description concerning the FDA regulatory status of the specific tests or drugs, we searched for the relevant information on the FDA website. Specifically, for diagnostic devices and tests, we searched the publicly accessible FDA 510(k) Premarket Notification database for information regarding the FDA clearance status of the products and devices that were identified from our grey literature search using the following method: we searched the 510(k) database7 by either product name, or applicant name (or the manufacturer). For drugs, we searched the Drugs@FDA database8 by using the active ingredient name. For each test or drug, the following information was recorded: company name; test modality/test name or active ingredient/drug name; FDA indications for use (when available) or indications per company literature; clearance by FDA; and whether or not the test (or drug) has been FDA cleared specifically for “vulnerable plaque.”

Finally, in order to map ongoing research on vulnerable plaque, we performed a systematic search of the Clinicaltrials.gov registry on 02/10/2010 to identify observational and interventional trials on vulnerable plaque. Protocols of retrieved entries were reviewed for use of predictors or outcomes relevant to the concept of vulnerable plaque and those studies were summarized.

## Study Eligibility Criteria

We identified abstracts of studies that fit a broad concept of vulnerable plaque. These included studies with the stated or implied aim of examining plaque features thought to be related to the susceptibility of an atherosclerotic plaque to cause a clinical event (e.g., myocardial infarction, angina, stroke, transient ischemic attack). These features included histopathological (i.e., thin-cap fibroatheroma, macrophage infiltration, presence of lipid core or intraplaque hemorrhage) or imaging (i.e., plaque echolucency and density, presence of ulceration or intraplaque hemorrhage and others) findings. We included primary studies or systematic reviews of studies that were conducted in living humans or on carotid or coronary artery tissue removed during procedures on living humans, or autopsy studies. We also collected narrative reviews, commentaries, and editorials on the concept of vulnerable plaque. Studies investigating associations between biomarkers (e.g., C-reactive protein) and clinical outcomes (e.g., acute coronary syndrome or stroke) or exploring the effect of treatment strategies (e.g., statins) on cardiovascular risk without explicit assessment of plaque vulnerability features (i.e., through imaging or histopathology evaluation) are outside the scope of this review and not discussed in this technical brief. Case reports were also excluded.

## Data Collection

From eligible primary studies, we extracted the following information from the available abstracts: study design (cross-sectional or longitudinal follow-up, prospective or retrospective collection of data); sample size; population (with or without history of carotid or coronary disease; living patients, tissue samples, or autopsy samples); predictor of interest (imaging characteristics of the plaque, histopathology, biomarkers, others); information on treatments; outcomes (clinical, imaging, or histopathological); and whether the study measured direct impact of a particular diagnostic tool on physician decision making or patient outcomes.