# List of Acronyms/Abbreviations

ACS: acute coronary syndrome
CMS: Centers for Medicare & Medicaid Services
CRP: C-reactive protein
MDCT: multi-detector computed tomography
FDA: Food & Drug Administration
IL-2: Interleukin-2
IL-2R: Interleukin-2 Receptor
IQR: interquartile range
IVUS: intravascular ultrasound
KQ: key question
Lp-PLA_2_: lipoprotein-associated phospholipase A_2_
MMP: matrix metalloproteinase
MRI: magnetic resonance imaging
PAPP-A: pregnancy-associated plasma protein A
PPAR-g: peroxisome proliferator-activated receptor-gamma
VEGF: vascular endothelial growth factor