# Summary and Implications

## Summary of Observations

We identified 890 citations that address questions in the three areas of interest and have enrolled older women who live with HIV/AIDS. Of these, only 37 (4 percent) studies reported results of interest among older women who live with HIV/AIDS or examined interactions between gender and older age that would allow extrapolation to this subgroup. An additional 494, 114, and 390 papers would have been eligible for the three areas of interest, had they reported the required information on women age 40 and over. This observation is not surprising, because the limited space of a published paper does not suffice for examining the many subgroups of interest. It is, however, congruent with the prediction of the Key Informants that evidence would be sparse. It may also have implications for future research investments, in that, in addition to gathering new data to address research gaps, a funder might consider a meta-analysis of individual-patient-level data from existing studies.

While some of the 37 eligible studies focused on populations facing obvious challenges, such as immigrant women,^62^ women who had suffered physical abuse,^56^ transgender women,^64^ and women recently released from prison,^69^ more studies are needed in these subgroups. No study focused on women caring for dependents, including children and grandchildren, or those diagnosed in old age. Similarly no study focused on women who face less obvious challenges, such as women who have adequate health insurance compared with those without adequate insurance. As was noted in our conversations with the Key Informants, women with adequate insurance coverage may paradoxically access a narrower range of resources, because they are not as widely exposed to community-based resources and other peer and social support services. In sum, the existing evidence base does not include a substantial number of studies that pertain directly to women who are over 40 and live with HIV/AIDS. We discuss the implications of this observation for future studies in the Next Steps section.

We identified eight generally small (of fewer than 200 participants) randomized trials that examined the impact of strategies for promoting healthy family and social relationships and healthier lifestyle (promoting medication adherence, smoking cessation, safer sexual behavior, and practices to prevent chronic disease). Most included psychosocial and health education components, but none included a comprehensive case-management-based approach that would also encompass medical, mental health, and sexually transmitted diseases prevention-specific components. Only a handful of nonrandomized studies evaluated the effectiveness of strategies for promoting care. We also identified eighteen studies of barriers to accessing care in general or specific services in particular (e.g. cancer screening), which most commonly examined barriers related to sociodemographic, psychosocial, and medical factors. A minority examined barriers related to cultural factors, experience with incarceration, or mental health. Several studies identified system-level barriers to engaging with care, including transportation, scheduling, insurance referrals, financial issues, and practical challenges, such as navigating a hospital building. Finally, very few studies examined the overall impact of insurance on outcomes, or the impact of comorbidity on the management of HIV infection or its progression. Thus, although we did not analyze the findings of the aforementioned studies in all clinical areas, it is highly unlikely that the identified body of evidence is close to maturity.

Our Web-based survey yielded a sizeable number of testing, housing, medical and mental health, and social support resources in the large cities, and limited availability of specific types of resources in the median and small cities in the six states. This survey was done to provide a high level summary of the number and density of resources that are registered. The fact that fewer resources exist in smaller-sizes cities is expected. The relative dearth of resources in smaller cities is particularly problematic for the geographically larger states, because the closest large urban center may be many miles away. Furthermore, even in urban centers where a very large number of resources may be concentrated, transportation can be a major problem. Traveling even a few miles in a big city can be difficult and time-consuming especially when one does not have private means of transportation and public transportation options are not convenient or are too expensive.

Indirectly, our Web-survey informs about how difficult it is for someone who is not intimately familiar with HIV care in a city or a state to obtain basic information, using only the Internet. Because the U.S. health system is not integrated, the exercise is revealing. One exception may be the locator.aids.gov Web page, which maps the location of certain types of resources throughout the U.S. However, locator.aids.gov is not exhaustive, does not provide detailed characteristics for each resource, and may not be fully up-to-date. It is possible to identify a list of facilities that are related to HIV care, and the states' Department of Health Websites provide information that one can use as a starting point. In general however, this information is not very detailed, and it is not entirely clear how often it is updated. One would have to proceed with personal communications with point persons in the various facilities, for example, to get a description of what they offer and how they operate, and what aspects of their care are specific to women who are older than 40 and are living with HIV/AIDS.

## Limitations

We developed an evidence map to describe the amount and type of practically available evidence, but did not summarize findings of eligible studies. For feasibility, we did not consider research completed longer than 10 years ago (specifically, earlier than 01/01/2005), because older empirical data are less likely to be relevant to today's setting. While it is plausible that earlier studies are applicable, important questions are often addressed by more recent replication studies, in which case they would be represented in the evidence map. Further, the more recent literature is probably more relevant for informing the future research agenda. We decided not to search EMBASE or any other large, international general database, and may have missed some relevant studies. Based on empirical data on the added utility of searching databases beyond PubMed, we deemed that the added benefit of searching multiple targeted databases was more cost and time efficient and would yield more relevant studies than a second large general database search.^91^

We did not conduct a detailed analysis of the 37 eligible papers. For example, we did not prioritize outcomes by their importance. Antiretroviral adherence, quality of life, smoking cessation, and engaging the internet are all outcomes that were assessed, but these outcomes do not span the set of measures that is pertinent for decision and policy making. Similarly, we did not do a detailed analysis of the risk of bias or the strength of evidence of individual studies or of the entire evidence-base, because these tasks were not relevant to the goal of this project, which was to describe the literature in broad terms. We believe that formal risk of bias and strength of evidence assessments would not materially affect the interpretation of our findings or change conclusions, because of the paucity of directly relevant data.

Because the main focus of the Technical Brief is to inform about the U.S. setting, we did not consider studies conducted exclusively in other countries. This is probably most defensible for empirical studies pertinent to the first two interest areas (impact of resources on outcomes, and impact of insurance), which deal with questions that are quite specific to the U.S. health system. Arguably, empirical studies in the third area of interest (diagnosis and management of comorbid conditions and predictors of patient-centered outcomes) are applicable irrespective of whether a study is conducted in the U.S. or in another country with advanced healthcare. However, given the interests of the OWH, and the limited available time and resources, we focused on U.S. studies only. To operationalize this, we limited our search to papers in which at least one author had a U.S. affiliation. In screening, we excluded a study only if it reported that it had been done exclusively outside the U.S.

We excluded studies not reporting empirical data, such as theory expositions, modeling studies of the effects of policies, opinion pieces, and non-systematic reviews. We did consider including systematic reviews, but did not find any. Because of limited time and resources, screening and data extraction were done by a single experienced reviewer. We believe that the overall picture of the research is accurate.

Finally, the Internet search was meant as a way to obtain an indication of the ease with which someone can identify available resources. It should not be interpreted as a suggestion of how patients and their providers should search for resources. It is difficult to know whether the identified resources are still in existence, or whether they are truly available to all patients. For example we did not check whether appointments were available, if all insurance was accepted, or if some subgroups, such as drug addicted individuals, were not welcome.

## Next Steps

### Research Needs

The evidence map identified only 37 studies that report information in the subgroup of older women who live with HIV/AIDS, or report any analyses to determine the influence of sex and older age on outcomes. These 37 studies they do not represent a mature evidence base. Specifically, these studies do not provide insights into approach to care that are specific to whether women have been diagnosed with HIV/AIDS at an earlier versus at an older age; have acute and chronic comorbidities, including substance abuse and mental health diagnoses; have different ethnic or racial descent; have different levels of insurance, income, wealth, social support, educational attainment; care for dependents; are undocumented immigrants; experience violence; have a history of incarceration; or identify as members of the LBGTQ community.

The evidence-base is even more sparse if one considers that the identified studies focused on different research questions. We identified few and small randomized trials and observational studies on strategies for engaging resources and promoting women's well-being, which cannot possibly cover the range of practically implementable interventions that should be examined. By their nature such interventions are complex, in that they have many versions, and their implementation and deployment can depend on the targeted population. Evaluating complex interventions is challenging, and often requires subgroup analyses and analyses of effect modifiers. In turn these generally require large sample sizes and robust and detailed data collection. We did not identify any such studies.

More generally, when the range of questions of interest is so large, and the directly applicable evidence-base is so limited, most, if not all, questions can be characterized as under-researched, and consequently, it is difficult to prioritize them for future research. For example, it is not obvious which of the aforementioned population subgroups represent more pressing priorities. It is also unclear which criteria to use to rank research priorities. One may, however, make some general observations, which may help those who prioritize research portfolia. Our suggestions are about practical ways to enrich the evidence-base on the issue at hand, and on research prioritization methods. We do not explicitly prioritize specific subpopulations or specific research questions, and we recommend that all research prioritization include input from women who are living with HIV/AIDS.

1. There is a need for better quality demographic information, as well as overall burden in the U.S. of women over the age of 40 living with HIV/AIDS.
2. A large amount of data have already been collected on women who are over 40 years and live with HIV in the context of studies that enrolled broader populations, but have not been analyzed for the subgroup of older women who were either diagnosed late in life or have been living with the disease for many years. In the this work we excluded 854 studies that ostensibly enrolled women who live with HIV/AIDS and are over 40 years old but provide no analysis that pertain directly to this subgroup. Substantial economy of resources can be had by encouraging re-analyses of existing datasets, with a focus on older women who live with HIV/AIDS.
3. However for some questions, it is possible that inferences about women who live with HIV/AIDS in the U.S. and are older than 40 years can be generalized from studies that included broader populations, including studies that have enrolled younger and older women or people who live outside the U.S. Relevant information may be transferred even from studies of patients who have other chronic or sexually transmitted diseases. A plausible approach would be to prioritize analyses of existing large studies to see whether and how inferences would change in subgroups defined by age or other factors. For example, if the natural course or general management of a chronic disease were not particularly affected by age in interaction analyses, data from younger and older people would be considered for high quality policy making. Other sources of this sort of data include claims data, the CDC Medical Monitoring Project, and large cohort studies, such as Women's interagency HIV study (WISE), the NA Accord, the SUN study, and Ryan White data (HRSA).
4. Observing the great successes of clinical research consortia that were formed to address medical questions, such as the AIDS Clinical Trials Group network, and the Women's Interagency Health Study we believe that encouraging analogous consortia for addressing questions related to health services research, barriers, social interventions, economics and other aspects of living and aging with HIV might be fruitful (for example, the AIDS Clinical Trials Group Network has surveyed physicians to identify barriers to providing care to people with HIV/AIDS^92^). Such consortia naturally result in networks of researchers oriented towards a comprehensive approach to care, inclusive of case managers, nurses, social workers, psychologists, and other experts, which could be leveraged to conduct high impact research and also to overcome practical challenges (e.g., the network can be used to refer a patient who moves to a new city to appropriate contact persons and services). It is also possible that these existing consortia could be convinced to expand their scope to include the research questions addressed in this Technical Brief.
5. Finally, with respect to research prioritization methods, we wish to bring attention to three families of approaches, which, to our knowledge, are not widely utilized in health and medicine to inform the planning of the future research agenda. We believe that these approaches could inform the deliberations of decisionmakers about which research to fund next.
  a. The first draws from statistical decision theory and economics and pertains to analyses of the expected value of information that would be obtained through new research.^93, 94^ The added value of this approach is that it can provide a ranking on which sources of uncertainty appear to be more pressing, according to the decisionmakers' criteria.
  b. The second relates to optimizing the future research agenda through the lens of portfolio selection theory, and draws from finance and operations research.^95, 96^ This approach may help construct a research portfolio that is diverse, and strikes a balance between exploitation (addressing questions that are readily answerable with little effort, and are likely to have impact) and exploration (addressing questions that may have a large impact, but may be higher-risk).
  c. The third pertains to multiple criteria decision making (MCDM), which is a theory for analyzing decisional problems (such as what research to fund next) that are subject to many, and potentially conflicting optimality criteria.^97, 98^ Implicit MCDM methods are already used in research prioritization exercises that are based on expert committees. However, a more formal application of MCDM principles may enhance the efficiency and clarity of current processes, and perhaps increase the likelihood of high quality decisions. MCDM approaches can be qualitative or quantitative (Multiple Criteria Decision Analysis).