# References

1 Berkelman RL, Heyward WL, Stehr-Green JK, et al. (1989). Epidemiology of human immunodeficiency virus infection and acquired immunodeficiency syndrome. Am J Med.
2 CDC. (2014). Diagnoses of HIV Infection in the United States and Dependent Areas, 2014. HIV Surveillance Report.
3 CDC. (2008). Diagnoses of HIV Infection in the United States and Dependent Areas, 2008. HIV Surveillance Report.
4 High KP, Brennan-Ing M, Clifford DB, et al. (2012). HIV and aging: state of knowledge and areas of critical need for research. A report to the NIH Office of AIDS Research by the HIV and Aging Working Group. J Acquir Immune Defic Syndr.
5 Guaraldi G, Zona S, Brothers TD, et al. (2015). Aging with HIV vs. HIV seroconversion at older age: a diverse population with distinct comorbidity profiles. PLoS One.
6 Linley L, Prejean J, An Q, et al. (2012). Racial/ethnic disparities in HIV diagnoses among persons aged 50 years and older in 37 US States, 2005-2008. Am J Public Health.
7 Nguyen N, Holodniy M. (2008). HIV infection in the elderly. Clin Interv Aging.
8 Friis-Moller N, Weber R, Reiss P, et al. (2003). Cardiovascular disease risk factors in HIV patients--association with antiretroviral therapy. Results from the DAD study. Aids.
9 Biggar RJ, Kirby KA, Atkinson J, et al. (2004). Cancer risk in elderly persons with HIV/AIDS. J Acquir Immune Defic Syndr.
10 Anastos K, Lu D, Shi O, et al. (2007). The association of bone mineral density with HIV infection and antiretroviral treatment in women. Antivir Ther.
11 Alcaide ML, Parmigiani A, Pallikkuth S, et al. (2013). Immune activation in HIV-infected aging women on antiretrovirals--implications for age-associated comorbidities: a cross-sectional pilot study. PLoS One.
12 Gimeno-Gracia M, Crusells-Canales MJ, Javier Armesto-Gomez F, et al. (2015). Prevalence of concomitant medications in older HIV+ patients and comparison with general population. HIV Clin Trials.
13 Burgess MJ, Zeuli JD, Kasten MJ. (2015). Management of HIV/AIDS in older patients-drug/drug interactions and adherence to antiretroviral therapy. HIV AIDS (Auckl).
14 Calvet GA, Grinsztejn BG, Quintana Mde S, et al. (2015). Predictors of early menopause in HIV-infected women: a prospective cohort study. Am J Obstet Gynecol.
15 Clark RA, Cohn SE, Jarek C, et al. (2000). Perimenopausal symptomatology among HIV-infected women at least 40 years of age. J Acquir Immune Defic Syndr.
16 Ferreira CE, Pinto-Neto AM, Conde DM, et al. (2007). Menopause symptoms in women infected with HIV: prevalence and associated factors. Gynecol Endocrinol.
17 Kanapathipillai R, Hickey M, Giles M. (2013). Human immunodeficiency virus and menopause. Menopause.
18 Kojic EM, Wang CC, Cu-Uvin S. (2007). HIV and menopause: a review. J Womens Health (Larchmt).
19 Schoenbaum EE, Hartel D, Lo Y, et al. (2005). HIV infection, drug use, and onset of natural menopause. Clin Infect Dis.
20 Tariq S, Delpech V, Anderson J. (2016). The impact of the menopause transition on the health and wellbeing of women living with HIV: A narrative review. Maturitas.
21 Dominguez S, Branco T, Haruperi T. (2013). Considerations for the long-term management of women living with HIV in Europe. Antivir Ther.
22 Hemkens LG, Bucher HC. (2014). HIV infection and cardiovascular disease. Eur Heart J.
23 D'Ascenzo F, Quadri G, Cerrato E, et al. (2015). A meta-analysis investigating incidence and features of stroke in HIV-infected patients in the highly active antiretroviral therapy era. J Cardiovasc Med (Hagerstown).
24 Ford N, Shubber Z, Meintjes G, et al. (2015). Causes of hospital admission among people living with HIV worldwide: a systematic review and meta-analysis. Lancet HIV.
25 Cortes YI, Yin MT, Reame NK. (2015). Bone Density and Fractures in HIV-infected Postmenopausal Women: A Systematic Review. J Assoc Nurses AIDS Care.
26 Imai K, Sutton MY, Mdodo R, et al. (2013). HIV and Menopause: A Systematic Review of the Effects of HIV Infection on Age at Menopause and the Effects of Menopause on Response to Antiretroviral Therapy. Obstet Gynecol Int.
27 Grov C, Golub SA, Parsons JT, et al. (2010). Loneliness and HIV-related stigma explain depression among older HIV-positive adults. AIDS Care.
28 Heckman TG, Heckman BD, Kochman A, et al. (2002). Psychological symptoms among persons 50 years of age and older living with HIV disease. Aging Ment Health.
29 Durvasula R. (2014). HIV/AIDS in older women: unique challenges, unmet needs. Behav Med.
30 Bing EG, Burnam M, Longshore D, et al. (2001). PSychiatric disorders and drug use among human immunodeficiency virus–infected adults in the united states. Archives of General Psychiatry.
31 Morrison MF, Petitto JM, Ten Have T, et al. (2002). Depressive and anxiety disorders in women with HIV infection. American Journal of Psychiatry.
32 CDC. (2015). HIV Among People Aged 50 and Older.
33 Gurung RA, Taylor SE, Kemeny M, et al. (2004). “HIV is not my biggest problem”: The impact of HIV and chronic burden on depression in women at risk for AIDS. Journal of Social and Clinical Psychology.
34 Control CfD, Prevention. (2014). Social determinants of health among adults with diagnosed HIV infection in 20 states, the District of Columbia, and Puerto Rico, 2010. HIV Surveillance Supplemental Report.
35 Martin DJ, Brooks RA, Ortiz DJ, et al. (2003). Perceived employment barriers and their relation to workforce-entry intent among people with HIV/AIDS. Journal of Occupational Health Psychology.
36 Fethers K, Marks C, Mindel A, et al. (2000). Sexually transmitted infections and risk behaviours in women who have sex with women. Sex Transm Infect.
37 Barroso J, Sandelowski M. (2004). Substance abuse in HIV-positive women. J Assoc Nurses AIDS Care.
38 Finfgeld-Connett DL. (2004). Treatment of substance misuse in older women: using a brief intervention model. J Gerontol Nurs.
39 Green KE, Feinstein BA. (2012). Substance use in lesbian, gay, and bisexual populations: an update on empirical research and implications for treatment. Psychol Addict Behav.
40 White Hughto JM, Reisner SL, Pachankis JE. (2015). Transgender stigma and health: A critical review of stigma determinants, mechanisms, and interventions. Soc Sci Med.
41 Wierckx K, Elaut E, Declercq E, et al. (2013). Prevalence of cardiovascular disease and cancer during cross-sex hormone therapy in a large cohort of trans persons: a case-control study. Eur J Endocrinol.
42 Gooren LJ, Wierckx K, Giltay EJ. (2014). Cardiovascular disease in transsexual persons treated with cross-sex hormones: reversal of the traditional sex difference in cardiovascular disease pattern. Eur J Endocrinol.
43 Gooren L, Lips P. (2014). Conjectures concerning cross-sex hormone treatment of aging transsexual persons. J Sex Med.
44 Ferron P, Young S, Boulanger C, et al. (2010). Integrated care of an aging HIV-infected male-to-female transgender patient. J Assoc Nurses AIDS Care.
45 Sevelius JM, Carrico A, Johnson MO. (2010). Antiretroviral therapy adherence among transgender women living with HIV. J Assoc Nurses AIDS Care.
46 Gupta SK, Eustace JA, Winston JA, et al. (2005). Guidelines for the management of chronic kidney disease in HIV-infected patients: recommendations of the HIV Medicine Association of the Infectious Diseases Society of America. Clin Infect Dis.
47 Fields-Gardner C, Campa A, American Dietetics A. (2010). Position of the American Dietetic Association: Nutrition Intervention and Human Immunodeficiency Virus Infection. J Am Diet Assoc.
48 Thompson MA, Aberg JA, Hoy JF, et al. (2012). Antiretroviral treatment of adult HIV infection: 2012 recommendations of the International Antiviral Society-USA panel. JAMA.
49 Masur H, Brooks JT, Benson CA, et al. (2014). Prevention and treatment of opportunistic infections in HIV-infected adults and adolescents: Updated Guidelines from the Centers for Disease Control and Prevention, National Institutes of Health, and HIV Medicine Association of the Infectious Diseases Society of America. Clin Infect Dis.
50 Lucas GM, Ross MJ, Stock PG, et al. (2014). Clinical practice guideline for the management of chronic kidney disease in patients infected with HIV: 2014 update by the HIV Medicine Association of the Infectious Diseases Society of America. Clin Infect Dis.
51 Wallace BC, Small K, Brodley CE, et al. (2012). Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proc. of the ACM International Health Informatics Symposium (IHI).
52 HIV and AIDS in the United States by Geographic Distribution.
53 (2014). Women and HIV/AIDS in the United States.
54 Cocohoba J, Comfort M, Kianfar H, et al. (2013). A qualitative study examining HIV antiretroviral adherence counseling and support in community pharmacies. J Manag Care Pharm.
55 Blackstock OJ, Haughton LJ, Garner RY, et al. (2015). General and health-related Internet use among an urban, community-based sample of HIV-positive women: implications for intervention development. AIDS Care.
56 Blackstock OJ, Blank AE, Fletcher JJ, et al. (2015). Considering care-seeking behaviors reveals important differences among HIV-positive women not engaged in care: implications for intervention. AIDS Patient Care STDS.
57 Blackstock OJ, Shah PA, Haughton LJ, et al. (2015). HIV-infected Women's Perspectives on the Use of the Internet for Social Support: A Potential Role for Online Group-based Interventions. J Assoc Nurses AIDS Care.
58 Burke-Miller JK, Cook JA, Cohen MH, et al. (2006). Longitudinal relationships between use of highly active antiretroviral therapy and satisfaction with care among women living with HIV/AIDS. Am J Public Health.
59 Fletcher FE, Buchberg M, Schover LR, et al. (2014). Perceptions of barriers and facilitators to cervical cancer screening among low-income, HIV-infected women from an integrated HIV clinic. AIDS Care.
60 Kempf MC, McLeod J, Boehme AK, et al. (2010). A qualitative study of the barriers and facilitators to retention-in-care among HIV-positive women in the rural southeastern United States: implications for targeted interventions. AIDS Patient Care STDS.
61 McDoom MM, Bokhour B, Sullivan M, et al. (2015). How older black women perceive the effects of stigma and social support on engagement in HIV care. AIDS Patient Care STDS.
62 Pivnick A, Jacobson A, Blank AE, et al. (2010). Accessing primary care: HIV+ Caribbean immigrants in the Bronx. J Immigr Minor Health.
63 Quinlivan EB, Messer LC, Adimora AA, et al. (2013). Experiences with HIV testing, entry, and engagement in care by HIV-infected women of color, and the need for autonomy, competency, and relatedness. AIDS Patient Care STDS.
64 Sevelius JM, Patouhas E, Keatley JG, et al. (2014). Barriers and facilitators to engagement and retention in care among transgender women living with human immunodeficiency virus. Ann Behav Med.
65 Stevens PE, Keigher SM. (2009). Systemic barriers to health care access for U.S. women with HIV: the role of cost and insurance. Int J Health Serv.
66 Tello MA, Jenckes M, Gaver J, et al. (2010). Barriers to recommended gynecologic care in an urban United States HIV clinic. J Womens Health (Larchmt).
67 Toth M, Messer LC, Quinlivan EB. (2013). Barriers to HIV care for women of color living in the Southeastern US are associated with physical symptoms, social environment, and self-determination. AIDS Patient Care STDS.
68 Vyavaharkar M, Moneyham L, Tavakoli A, et al. (2007). Social support, coping, and medication adherence among HIV-positive women with depression living in rural areas of the southeastern United States. AIDS Patient Care STDS.
69 Williams CT, Kim S, Meyer J, et al. (2013). Gender differences in baseline health, needs at release, and predictors of care engagement among HIV-positive clients leaving jail. AIDS Behav.
70 Teti M, Bowleg L, Cole R, et al. (2010). A mixed methods evaluation of the effect of the protect and respect intervention on the condom use and disclosure practices of women living with HIV/AIDS. AIDS Behav.
71 Feaster DJ, Brincks AM, Mitrani VB, et al. (2010). The efficacy of Structural Ecosystems Therapy for HIV medication adherence with African American women. J Fam Psychol.
72 Feaster DJ, Mitrani VB, Burns MJ, et al. (2010). A randomized controlled trial of Structural Ecosystems Therapy for HIV medication adherence and substance abuse relapse prevention. Drug Alcohol Depend.
73 El-Bassel N, Jemmott JB, Landis JR, et al. (2011). Intervention to influence behaviors linked to risk of chronic diseases: a multisite randomized controlled trial with African-American HIV-serodiscordant heterosexual couples. Arch Intern Med.
74 Mitrani VB, McCabe BE, Burns MJ, et al. (2012). Family mechanisms of structural ecosystems therapy for HIV-seropositive women in drug recovery. Health Psychol.
75 Manuel JK, Lum PJ, Hengl NS, et al. (2013). Smoking cessation interventions with female smokers living with HIV/AIDS: a randomized pilot study of motivational interviewing. AIDS Care.
76 DeMarco RF, Chan K. (2013). The Sistah Powah structured writing intervention: a feasibility study for aging, low-income, HIV-positive Black women. Am J Health Promot.
77 Dutcher MV, Phicil SN, Goldenkranz SB, et al. (2011). “Positive Examples”: a bottom-up approach to identifying best practices in HIV care and treatment based on the experiences of peer educators. AIDS Patient Care STDS.
78 Sullivan KA, Schultz K, Ramaiya M, et al. (2015). Experiences of women of color with a nurse patient navigation program for linkage and engagement in HIV care. AIDS Patient Care STDS.
79 Chander G, Hutton HE, Lau B, et al. (2015). Brief Intervention Decreases Drinking Frequency in HIV-Infected, Heavy Drinking Women: Results of a Randomized Controlled Trial. J Acquir Immune Defic Syndr.
80 Echenique M, Illa L, Saint-Jean G, et al. (2013). Impact of a secondary prevention intervention among HIV-positive older women. AIDS Care.
81 Kupprat SA, Dayton A, Guschlbauer A, et al. (2009). Case manager-reported utilization of support group, substance use and mental health services among HIV-positive women in New York City. AIDS Care.
82 Proeschold-Bell RJ, Reif S, Taylor B, et al. (2016). Substance Use Outcomes of an Integrated HIV–Substance Use Treatment Model Implemented by Social Workers and HIV Medical Providers. Health & Social Work.
83 Sarnquist CC, Soni S, Hwang H, et al. (2011). Rural HIV-infected women's access to medical care: ongoing needs in California. AIDS Care.
84 Abel E. (2007). Women with HIV and stigma. Family & community health.
85 Weiss SM, Tobin JN, Lopez M, et al. (2015). Translating an Evidence-Based Behavioral Intervention for Women Living with HIV into Clinical Practice: The SMART/EST Women's Program. Int J Behav Med.
86 Cook JA, Burke-Miller JK, Grey DD, et al. (2014). Do HIV-positive women receive depression treatment that meets best practice guidelines?. AIDS Behav.
87 Galarraga O, Salkever DS, Cook JA, et al. (2010). An instrumental variables evaluation of the effect of antidepressant use on employment among HIV-infected women using antiretroviral therapy in the United States: 1996-2004. Health Econ.
88 Neblett RC, Hutton HE, Lau B, et al. (2011). Alcohol consumption among HIV-infected women: impact on time to antiretroviral therapy and survival. J Womens Health (Larchmt).
89 Triant VA, Lee H, Hadigan C, et al. (2007). Increased acute myocardial infarction rates and cardiovascular risk factors among patients with human immunodeficiency virus disease. J Clin Endocrinol Metab.
90 Lucas GM, Griswold M, Gebo KA, et al. (2006). Illicit drug use and HIV-1 disease progression: a longitudinal study in the era of highly active antiretroviral therapy. Am J Epidemiol.
91 Halladay CW, Trikalinos TA, Schmid IT, et al. (2015). Using data sources beyond PubMed has a modest impact on the results of systematic reviews of therapeutic interventions. J Clin Epidemiol.
92 Bini EJ, Kritz S, Brown LS, et al. (2011). Barriers to providing health services for HIV/AIDS, hepatitis C virus infection and sexually transmitted infections in substance abuse treatment programs in the United States. J Addict Dis.
93 Pratt JW, Raiffa H, Schlaifer R. (1995). Introduction to statistical decision theory.
94 Meltzer DO, Smith PC. (2011). Theoretical issues relevant to the economic evaluation of health technologies. Culyer AJ, Pauly MV, Newhouse JP, McGuire TG, Barros PP, editors. Handbook of Health Economics.
95 Bisias D, Lo AW, Watkins JF. (2012). Estimating the NIH efficient frontier. PloS one.
96 Markowitz H. (1952). Portfolio selection. The journal of finance.
97 Figueira J, Greco S, Ehrgott M. (2005). Multiple criteria decision analysis: state of the art surveys.
98 Greco S, Ehrgott M, Figueira JR. (2010). Trends in multiple criteria decision analysis.