# Objectives

The OWH commissioned this Technical Brief through AHRQ's Evidence-based Practice Center Program to provide background for an upcoming OWH meeting. At this meeting, local and national HIV policy experts will help OWH prioritize future research based on the gaps in the evidence identified in this paper. The OWH specified age 40 as an operational age cutoff to identify premenopausal women who are less likely to bear children, as well as peri- and postmenopausal women. The OWH posed a broad set of guiding questions to communicate their priorities. We organized these guiding questions into three conceptual areas:

In Area 1 (resources) we included questions about strategies and barriers for engaging with resources that aim to enhance the wellbeing of older women who live with HIV/AIDS Example guiding questions include:

- What is the impact of health care services, programs, and policies focused on these women (in medical settings, in community settings, and in common sub-populations, such as women who have experienced trauma, incarceration, violence, poverty, or substance abuse)?
- What services and programs are most likely to keep these women in health care (either medical or community based care)?
- What resource-level factors affect initial or continued engagement with a program?
- What barriers do these women face in their initial or continued engagement with a program?
- What are the individual-level characteristics of those who stay in the continuum of care (sociodemographic or cultural, psychosocial, experience with incarceration, or clinical, personal, and family medical and mental history)?
- Where are the gaps in knowledge about effective programs for these women?

In Area 2 (insurance) we grouped questions about measuring the impact of insurance on the wellbeing of older women who live with HIV/AIDS. Example questions include:

- What is the effect of insurance coverage for older women who live with HIV/AIDS on the outcomes in Areas 1 and 3?
- Do the Affordable Care Act requirements for HIV/AIDS care impact the care these women receive?

In Area 3 (comorbidities) we grouped questions about the diagnosis or management of comorbidities, or the role of comorbidities in predicting all-cause mortality or HIV-related disease progression. Example questions include:

- What factors impact mortality, quality of life, health, and psychosocial outcomes in older women who live with HIV/AIDS?
- What tools are readily available or routinely used to screen, diagnose, monitor or otherwise manage such women who also have co-occurring conditions?
- Are any such tools reliable in the entire spectrum of severity represented in older women who live with HIV/AIDS?

With input from a diverse panel of content experts and other stakeholders (Key Informants), we develop an evidence map to characterize the existing empirical studies of strategies for improving the comprehensive care of older women who live with HIV/AIDS that apply to today's U.S. setting. We outline resources available to these women in a purposeful sample of six states, and illustrate the importance of having integrated care through four vignettes.