# Methods

Part one of the Technical Brief comprises an evidence map of the published literature on questions pertinent to women over 40 who live with HIV/AIDS. Part two provides a high-level overview of the amount and type of resources that appear to be available to these women in a purposeful sample of six U.S. states. Part three presents four clinical vignettes.

## Key Informants

We formed a panel of eight Key Informants comprising experts in the care of HIV patients, and especially of older women, nationally recognized researchers, policy makers, state government (department of health) officials, and nationally recognized advocates for women who live with HIV/AIDS. We solicited the panel's input in two teleconferences and over email until we deemed that we had sufficiently discussed all of the relevant themes. The interactions with the Key Informant Panel were facilitated by the EPC and included the following questions:

1. What are the salient differences between women over 40 compared with younger women living with HIV/AIDS?
2. Which subgroups face more challenges/barriers? What are the major barriers to engaging with care or other resources?
3. What are commonly accepted ways to organize medical, behavioral or social intervention-based strategies for improving the wellbeing of women who live with HIV/AIDS?
4. How does a woman, her physician, or her case manager go about identifying what resources are available to her?

Based on feedback from Key Informant discussions we refined study eligibility criteria and data extraction items for the evidence map. The discussions with the key informants are discussed further in the Summary and Implications section of this report.

In addition, Key Informants conjectured that very few publications would be eligible in the three areas of interest and that some observations that were important to them were unlikely to be gleaned from an evidence map of the published literature. These include the central role of case-managers in helping people navigate a “highly fragmented” system, the risk of underdiagnosis of HIV infection in older women who are sexually active, the issues faced by women who care for dependents, and the issues faced by women who are medically well but emotionally or economically burdened or socially stigmatized. As described in the Vignettes section, we collaborated with a social worker from the Brown University-affiliated Miriam Hospital to identify and present four vignettes that capture the aforementioned themes. We use these real but anecdotal cases to paint a more vivid picture about the importance of these themes.

## Evidence Map

We created a compendium of empirical studies that apply to women over 40 who live with HIV/AIDS and inform the three areas of interest described in the guiding questions. The first area includes studies that measure the impact of strategies for engaging with existing resources, including medical, social, or other services that aim to improve the lives of women who live with HIV/AIDS on a range of outcomes, or programs that bundle several such services. We also include studies describing barriers to access of such resources. The second area includes studies that measure the impact of various levels of insurance coverage on outcomes. The third area pertains to studies that assess the performance of diagnostics for co-occurring disease, or assess the effects of treating co-occurring diseases (such as depression or heart disease) or risk factors (such as high blood pressure or low bone mineral density) on person-level outcomes. Figure 1 summarizes the three areas of interest.

Figure 1 Analytic framework

For the first interest area (measuring the impact of strategies for engaging with resources), women over 40 who live with HIV/AIDS may engage with resources transiently or in a continued fashion, and this engagement affects person- and system-level outcomes. Personal or resource-level barriers or modifiers can affect the likelihood of engaging or continue engaging with a resource. The second interest area includes studies that measure the overall impact of insurance on person- and system-level outcomes, irrespective of whether it is mediated by women's use of specific resources., Effect modifiers can affect the likelihood that insurance impacts on outcomes. The third interest area includes studies that assess the performance of tests for diagnosing co-occurring diseases, treatments for managing such diseases on person-level outcomes, and predictive models of all-cause mortality or HIV infection progression.

The Figure shows an analytic framework for the evidence map, for the three interest areas. For the first interest area (measuring the impact of resources), older women who live with HIV may engage with resources, transiently, or in a continued fashion, and this engagement affects person- and system-level outcomes. A range of modifiers affect the likelihood of engaging or continue engaging a resource. The second interest area includes studies that measure the overall impact of insurance on person- and system-level outcomes, irrespective of whether it is mediated by women's use of resources. Again, a range of modifiers affect the likelihood that insurance impacts on outcomes. The third interest area includes studies that assess diagnosing the presence of comorbidities, managing comorbidities or assess predictors other than comorbidities on the risk of person-level outcomes.

### Eligibility Criteria

Eligible studies pertained to women aged 40 years and older who live with HIV. Studies with broader enrollment, e.g., enrolling both sexes or all ages were excluded, unless they reported results for strata where at least 75 percent of the participants were women over 40 years or modeled interactions between gender and an older-age cutoff.

All patient-level and system-level outcomes were eligible. Examples of person-level outcomes included clinical outcomes, such as mortality and morbidity, mental health, function, quality of life as measured by each study, and out-of-pocket costs. Examples of system-level outcomes included total costs or changes in the proportion or number of women undergoing a public health intervention, such as screening or engaging with an eligible resource.

Eligible resources were services providing medical, behavioral, or social support, or programs that bundle several such services. This definition encompasses all hospital-, clinic-, or community-based strategies that promote women's wellbeing. The following are indicative examples: A case-management intervention that assists women to apply for Ryan White programs or housing subsidies is an example of a social support service. A clinic providing routine HIV, general medical, or mental health care represents a service providing medical support. A program for helping women facing addiction problems may provide medical, behavioral, and social support services.

In Area 1 (resources), we included randomized trials, nonrandomized comparisons of cohorts, or before-after studies that measured the relationship between using an eligible resource and person- or system-level outcome. We also included studies that examined modifiers of the relationship between using an eligible resource and eligible outcomes.^a^ We also included cohorts, surveys, or qualitative research studies describing barriers faced by women when engaging with eligible resources.

In Area 2 (insurance), we included randomized trials, nonrandomized comparisons of cohorts, and before-after studies measuring the association between various levels of insurance coverage (including none) and person- or system-level outcomes.

In the Area 3 (comorbidities), we included (1) cross-sectional, case-control or cohort studies of the sensitivity and specificity of tests, including imaging tests, laboratory measurements, and clinical scores, for diagnosing the presence of co-occurring diseases, including but not limited to infections (such as hepatitis C, tuberculosis, and opportunistic infections, cancers, or dementia); (2) randomized and nonrandomized comparative studies of the management of co-occurring diseases^b^ or established risk factors for major diseases^c^; or (3) predictive models of all-cause mortality or of HIV infection progression.

We excluded studies that analyzed fewer than 10 women who are older than 40 and live with HIV/AIDS, because they were unlikely to yield precise or broadly applicable conclusions. For feasibility, we excluded studies completed longer than 10 years ago, because older empirical data are less likely to be relevant to today's setting. Because the main focus of the Technical Brief is to inform about the U.S. setting, we did not include studies conducted exclusively in other countries. We excluded studies not reporting empirical data, such as theory expositions, modeling studies of the effects of policies, and opinion pieces.

### Literature Identification and Tracking

A medical librarian designed and implemented searches in PubMed, PsycINFO, CINAHL, and SocINDEX for terms related to HIV or AIDS, crossed with general terms on interventions, policies, services, or programs. We limited the search to English language reports published after 01/01/2005 and having at least one author with a U.S. affiliation. The search was last run on February 10, 2016 and is reported in full in Appendix A.

Four reviewers screened the same 400 abstracts to pilot citation screening criteria and ensure their uniform understanding and application. We iteratively assessed discrepancies as a group until all screeners were uniform in their assessments. After this pilot phase, citations were single-screened by a human reviewer, and double-checked against the predictions of the machine learning algorithms implemented in Abstrackr, a system for semi-automating citation screening tasks developed by Brown University's Center for Evidence-based Medicine.^51^ All potentially eligible citations were retrieved and screened in full text for eligibility. We did not record reasons for exclusion at the abstract level.

Full text articles were evaluated for eligibility by a single reviewer, after a training period to ensure consistency between reviewers. For all papers reviewed in full-text we recorded reasons for exclusion. For papers on studies that likely fulfill all criteria but are excluded only because they do not report subgroup-specific information or pertinent interaction analyses, we recorded to which area of interest the paper would be included had it reported the required information. This provides an indication of the volume of information that is potentially available for secondary data analyses.

### Data Abstraction and Data Analyses

From each eligible article we extracted bibliographic information (first author, journal, year of publication), study name (as applicable), location where the study was run, enrollment years, sample size of women who live with HIV/AIDS (largest analysis per study for women of all ages and over 40 years), study design (randomized trial, nonrandomized comparative, observational), and for comparative studies, the compared interventions.

Studies rarely reported detailed information on women who are older than 40 years and live with HIV; thus, we recorded the following information for all women enrolled in each study: mean age and age range or proportion of women older than an eligible age cutoff; menopausal status (percent pre-, peri- or post-menopause); percent having been diagnosed with HIV in older age (at 40 years or older); race ethnicity (percent White, Black/African American, Asian, Latino/Hispanic, Native American, Pacific Islander, other); insurance coverage status (percent with no insurance, private insurance, Medicare, Medicaid or other public); percent having dependent care, having a supporting partner or other social support (as defined by study), experiencing violence at home, being undocumented immigrants, using drugs (when results were reported per substance, the highest percentage reported), having experienced incarceration, having a history of mental health challenges; percent of transgender women, lesbian women, women in monogamous relationships; median income, percent below the Federal poverty level; percent who completed high school; and percent unemployed.

For studies in the first area of interest (measuring impact of strategies for engaging with resources or barriers to engaging with resources), we recorded the name of the program (if applicable), its objectives (as described by the authors), and whether it included medical services (general or specialist care, including mental health and substance abuse); psychosocial (assistance with applications for housing, financial support, AIDS Drug Assistance Program enrollment, support groups, peer-based programs, etc.); case management; general or HIV specific health education; and services aimed at reducing HIV or other sexually transmitted disease (STD) transmission; along with the primary outcome by which the impact of the resource was measured (the first-mentioned outcome in the results, if there were several). For studies of barriers, we recorded what these barriers hindered (e.g., screening for cancer, engaging in care), along with categories of person-level (sociodemographic, cultural, psychosocial including insurance status, experience with incarceration, medical history, mental health) and system-level modifiers that were examined in each study.

For studies in the second area of interest on the overall effect of insurance, we recorded the reported levels of insurance coverage and the outcomes by which the impact of insurance coverage was measured.

For the third area of interest, we extracted whether the study was about the diagnosis or management of a co-occurring condition or risk factor and the type of condition or risk factor (mental health, cardiovascular disease, etc.). We also recorded whether the paper described a predictive model of all-cause mortality or HIV infection--sociodemographic, psychosocial (including insurance status), cultural, experience with incarceration, medical, mental health progression, and, if yes, the category of predictive factors it examined.

All data were extracted in a predefined electronic form by a single investigator. Extracted data are in Appendix D. We used descriptive statistics to summarize findings. Due to the nature of the project, we did not make strength of evidence assessments for individual studies or for the whole evidence-base.

## Illustration of Salient Issues

### Vignettes from the Immunology Clinic at Miriam Hospital, RI

One of the key uses of evidence maps is to identify research gaps. We present four anecdotes (vignettes) that illustrate different issues in the care of women who live with HIV/AIDS. We collaborated with a social worker who coordinates the comprehensive management of people who live with HIV in a well-integrated and nationally recognized center at the Immunology Clinic at the Miriam Hospital in Rhode Island. This clinic was chosen because our team's clinical expert works there and gave us detailed information. The vignettes touch on the following themes: the role of case-managers in coordinating people's care and helping people navigate a “highly fragmented” system; the risk of underdiagnosis of HIV infection and concomitant late-initiation of treatments in older women who are sexually active; the range of issues faced by older transgender women, women who live with HIV/AIDS while caring for dependents, and women who are medically well but emotionally burdened or socially stigmatized.

All vignettes are factual, but all identifying information has been redacted and pseudonyms are used. There are no risks to the respective patients. The four anecdotes are provided for illustration. They do not touch on all important issues faced by women who live with HIV/AIDS. We do not imply that the described management of patients in the vignettes was optimal, and we do not use the vignettes as evidence to support specific conclusions. In addition, the experiences of a single social worker may not be representative of experiences of other staff members in the same facility or experiences of staff members at other facilities, and extrapolations to other settings should be avoided.

## Outlining Available Resources in a Purposeful Sample of Six States

Because the published literature is unlikely to provide descriptions of resources that are in place in the U.S., we conducted a Web site survey of the amount and type of resources that appear to be available to older women who live with HIV/AIDS in a purposeful sample of six states, namely Rhode Island, New York, Texas, California, Mississippi, and Alabama. These states are diverse in terms of geographical location, HIV prevalence overall and among women,^52^ political culture, health systems, per capita income, availability of public transportation, and proportion of women with HIV who are foreign born or belong to a racial minority. For example, New York, Texas, and California are among the regions with the highest number of women living with HIV/AIDS infection in the Nation.^53^ Alabama and Mississippi have dis-proportionally large number of African American women who live with HIV/AIDS. This sample is purposeful: it is not meant to be a “representative sample” of the 50 states,^a^ but rather aims to illustrate variability.

We performed systematic Web searches, emulating a Web-savvy, persistent patient or provider who is not familiar with the resources available in these states, and who wishes to find information about them. This approach was chosen because it may inform, at a high level, on the density of different type of resources in these states. It corresponds to an “upper bound,” Of what might be available to an educated patient or, more likely a case-worker, who needs to find out what resources are available in an unfamiliar area. Clearly, some older women living with HIV/AIDS are unlikely to have this sort of access to or familiarity with the Internet, but the patient navigators and social workers who work with them should.

We summarize our findings to provide an indication of how easily one can identify local resources. To capture variability between urban and rural settings we summarize the number of AIDS.gov-registered facilities providing HIV testing, housing assistance, health services, Ryan White-funded HIV Care entities, mental health, substance abuse and family planning services in three cities in each state. We selected the largest, smallest, and median city in terms of population size in the most recent census on states' governmental Web sites. We obtained information by searching AIDS.gov's program locator (https://locator.aids.gov/), for a 20 mile radius around from each city center. We also conducted general web searches and searches of Web sites of departments of health in the six states.

a As established in the Key Informant discussions, person-level modifiers include sociodemographic factors (e.g., race/ethnicity, income, marital status, insurance coverage, highest educational attainment), cultural factors (e.g., immigrant status), psychosocial factors (e.g., social or family support), experience with incarceration, or clinical, personal and family medical and mental history factors (e.g., cancer, heart disease, addition problems, mental health diagnosis). Examples of resource-level modifiers are case management, or using a multidisciplinary team.

b Such as cancer, infections (including hepatitis C, human papilloma virus [HPV], tuberculosis, osteomyelitis, AIDS defining infections such as Pneumocystis carinii pneumonia [PCP], etc.), neurocognitive impairment (including HIV-associated dementia), cardiovascular disease, mental health (depression, PTSD, bipolar, schizophrenia), addiction and substance abuse (heroin, cocaine, prescription drugs, alcohol, smoking, “party” drugs such as MDMA [Ecstasy], flunitrazepam [Rohypnol], ketamine), musculoskeletal disease (e.g. osteoporosis, rheumatoid arthritis) and other age-associated end-organ diseases not mentioned here (by reviewer consensus).

c Such as hypertension, hyperlipidemia, diabetes, obesity, osteoporosis, and low bone mineral density measurements.

a There is no “representative sample” of the 50 U.S. states in the context of the current research project.