# Introduction

## Background

At the end of 2013, an estimated 933,941 people were living with human immunodeficiency virus (HIV) infection in the United States. While in its early years the epidemic affected primarily males and young people,^1^ nowadays the population living with HIV/AIDS is approximately 24 percent women and its age composition has shifted.^2^ The percentage of people living with HIV/AIDS aged 50 years and older grew from 24 percent in 2005 to 42 percent in 2013, and is projected to top 50 percent by 2020.^2-4^ Thus, the management of this older population represents a relatively new challenge. The population of older people who live with HIV/AIDS is heterogeneous with respect to factors (such as gender) that are associated with length and quality of life.^2^ The Centers for Disease Control and Prevention (CDC) HIV Surveillance Report does not report the number of older women living with HIV/AIDS.^2^ Many entities, including the Office for Women's Health (OWH), consider these women a priority population.

This Technical Brief (TB) aims to identify and characterize the empirical studies of strategies for the comprehensive management of older women living with HIV/AIDS. For this report, we define “older” as over the age of 40, and include transgender women (people who were born male but identify as women). The OWH chose age 40 as an operational age cutoff to identify premenopausal women who are less likely to bear children, as well as peri- and postmenopausal women

Age at HIV/AIDS_infection, rather than age at diagnosis, may be important. The population of women over 40 who live with HIV/AIDS comprises women who were diagnosed with the virus at young age and have survived into their middle and late years and women who were diagnosed with HIV at an older age, for this report, after age 40. According to the CDC, 8.6 percent of the 39,718 recently diagnosed people in 2014 were women aged 40 or older.^2^ The natural history and prognosis of HIV/AIDS in those who were newly diagnosed at an older age appear to be distinct from those newly-infected at an older age.^5^ Further, compared with people who were infected young, people contracting HIV at an older age are not diagnosed as promptly and tend to start treatment at a more advanced stage. Possible explanations include that older people who are sexually active may be less aware of their risk; may underestimate the likelihood that their partners can have HIV; may be more likely to engage in unprotected sex (because pregnancy is not an issue); and may be less likely to discuss sexual health with their doctors than younger people.^6^ In addition, providers' own implicit biases, assumptions, or lack of comfort speaking about sexual health may prevent them from offering HIV testing as readily to older patients.

Aging with HIV infection also presents special challenges for preventing and managing comorbid conditions. Older women with HIV/AIDS may have an increased risk for cardiovascular disease, osteoporosis, and certain cancers than their uninfected counterparts.^7-10^ HIV-positive antiretroviral-treated older women who achieve viral suppression are in a generalized status of immune activation and therefore may be at an increased risk of age-associated end-organ diseases compared with uninfected age-matched controls.^11^ Polypharmacy is another common concern because of the many comorbidities are related to HIV or aging, including cardiovascular disease, hypertension, type 2 diabetes, obesity, chronic kidney disease, bone disease, hyperlipidemia, cancer, depression, and neurocognitive impairment. Interactions between antiretrovirals and the numerous other medications taken for these chronic diseases can pose significant clinical problems.^12, 13^

Women over 40 living with HIV/AIDS also face issues related to the interaction between reproductive hormones, HIV/AIDS, and antiretroviral treatments. Some women may still have childbearing potential and will have unique contraceptive or fertility needs. There have been inconsistent reports regarding HIV and menopause. Some studies report menopause at an earlier age among women living with HIV/AIDS compared with uninfected women.^14-20^ Some studies suggest that women with HIV have more vasomotor symptoms (e.g., hot flashes, night sweats) and mood issues during menopause.^20^ However, many of these studies have a small sample size, involve only cohorts of women living with HIV/AIDS without a control, or do not account for confounding factors, such as history of drug use, current smoking, lower BMI, or race. Menopause may affect a woman's quality of life by altering her mood, causing sexual dysfunction, or accelerating the onset and progression of chronic diseases of aging, including cardiovascular disease, hypertension, diabetes, and reduced bone mineral density.^21-26^ The pharmacological interactions between hormone therapy and antiretroviral treatments are not well understood. No published data have assessed the safety and efficacy of hormone therapy on symptoms of menopause, cardiovascular risk, and bone disease among women living with HIV/AIDS.^20^

Older women with HIV face challenges related to mood and psychosocial wellbeing. Compared with older women without HIV, older women with HIV infection are more likely to be depressed and lonely,^27, 28^ and many women are further burdened with taking care of elderly parents or grandchildren.^29^ Depression in clinic populations of people living with HIV/AIDS has been found to be two to three times higher than in general community populations, and as much as four times higher among women living with HIV/AIDS than in HIV-seronegative women.^30, 31^ The stigma associated with HIV infection is a particular concern among older women living with HIV, who may already feel isolated because they have lost partners and friends;^32^ Stigmatization can contribute to depression and worry, negatively affecting quality of life, and may prevent women from disclosing their HIV status or from seeking HIV care.^33^

African American/Black and Latina/Hispanic women are disproportionally affected by HIV, compared with women of other race/ethnicities. An estimated 61 percent of women who were living with HIV/AIDS in 2014 were African American, 17 percent were Latinas, and 17 percent were White, although further breakdown by age and race/ethnicity is not readily available in the published CDC Surveillance Report.^2^ Race is often a marker of socioeconomic and demographic factors related to health inequities, including low educational attainment, low income or poverty, low health literacy, lower proportion with insurance, higher rates of comorbidity, and higher rates of drug abuse, all of which may have a bearing on the comprehensive management of women living with HIV/AIDS.

HIV rates vary widely by geographic location.^2^ In addition, there are indications that, among women older than 24 years, HIV rates are highest living in areas where more than 21 percent of residents were below the Federal poverty level.^34^ In some cases, women living with HIV/AIDS may have to stop working or reduce their income either because of the illness or in order to qualify for medical care, treatment, and associated services.^35^

Special consideration should be given to women who identify as lesbian, bisexual or transgender (assigned male sex at birth but identify as women). For women who identify as lesbian, HIV infection may be diagnosed belatedly. Although HIV transmission risk is generally considered to be low in unprotected lesbian sex, a woman may have contracted the virus from a past heterosexual experience or through other routes, such as injection drug use.^36-39^ Transgender women are also vulnerable for medical and social reasons. They are often subjected to violence and face depression and stigma.^40^ They may get hormonal therapy to change their appearance, which can impact their risk for cardiovascular disease, osteoporosis, and perhaps cancers.^41-45^ Finally, transgender women still face health issues associated with their biological sex, such as prostate cancer,^41-43^ and this should be factored into their medical care.

Ideally, the care of older women living with HIV/AIDS should support patient-centered approaches to managing HIV and comorbidities; incorporate patient goals, including quality of life issues; and integrate biomedical, behavioral, and social interventions.^13^ However, the current system of care in the United States does not support a comprehensive model that can provide a tailored approach for older women living with HIV/AIDS. For example, women have to move between a primary care provider, a gynecologist, and several specialists for their medical needs. Many health care providers have not been trained to deal with an older population with HIV, and relatively few centers provide comprehensive psychosocial and case-management services for older women living with HIV/AIDS. Even current guidelines for HIV testing, HIV treatment, and the management of conditions that accompany aging do not explicitly address the older patient with several comorbidities.^46-50^