# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Kathryn Anastos, M.D.
  Albert Einstein College of Medicine
  New York, NY
- Dawn Averitt
  Women's Research Initiative on HIV/AIDS
- Mark Brennan-Ing, Ph.D.^*^
  AIDS Community Resources Initiative of America (ACRI)
  New York, NY
- Gina Brown, M.D.^*^
  Office of Women's Health (NIH)
  Washington, DC
- Naina Khanna^*^
  Positive Women's Network – USA
  Oakland, CA
- Paul Loberti, M.P.H.
  Executive Office of Health and Human Services, RI Medicaid Division,
  HIV Provision of Care & Special Populations Unit
  Providence, RI
- Deborah Parham Hopson, Ph.D., M.S.P.H.,
  R.N., RADM, USPHS
  Ryan White HIV/AIDS Program
  Washington, DC
- JoAnn V. Pinkerton, M.D., N.C.M.P.^*^
  Executive Director, The North American Menopause Society
  Cleveland, Ohio
  Professor of Obstetrics and Gynecology
  Division Director Midlife Health
  University of Virginia Health Center
  Charlottesville, Virginia
- William Short, M.D., M.P.H.
  University of Pennsylvania School of Medicine
  Philadelphia, PA

* This Key Informant also provided comments on the draft report.