# Acknowledgments

We are indebted to Holly A. Batura, LMHC, who is a social worker and counselor at the Miriam Hospital, RI, for her help in describing the services provided in her facility, and for identifying and helping us present in a factually accurate manner four vignettes that illustrate key issues without compromising people's privacy.