# Findings

## Evidence Map

We screened 9054 unique abstracts for eligibility, of which 1763 were selected for full text review. In the end, 32, 7, and 8 papers were eligible for the three areas of interest, respectively (Figure 2). Of the citations that were excluded in full text review, 854 were excluded because they did not provide information on strata of women who live with HIV/AIDS and are at least 40 years old or did not analyze interactions between gender and older age. These studies typically enrolled a broader population, but opted to not provide results or analyses for the population of interest, and would be otherwise eligible. Thus, in principle, an additional 494 papers would have been eligible for interest area 1 (284 on measuring the impact of a resource and 271 characterizing barriers to accessing resources); another 114 for area 2, on the overall impact of insurance; and another 390 for area 3, including 280 papers on the diagnosis or management of comorbidities and 211 on models predicting all-cause mortality or disease progression based on treatments received and other factors. Details of these studies are listed in Appendix B. A list of studies excluded for other reasons is in Appendix C.

Figure 2 Literature flow

* “Not relevant”: These studies were excluded on the grounds of more than one reason (e.g., did not describe eligible outcomes of eligible programs in an eligible population).

The Figure shows the flow of the literature for the project. We screened 9054 unique abstracts for eligibility, of which 1763 were selected for full text review. Of these 853 were excluded because they did not provide information on strata of women who live with HIV and are at least 40 years old or did not analyze interactions between gender and older age. Of these 494 papers would have been eligible for interest area 1 (284 on measuring the impact of a resource and 271 characterizing barriers to accessing resources), 114 for area 2, on the overall impact of insurance, and 389 for area 3, including 280 papers on the diagnosis or management of comorbidities and 211 on models predicting all-cause mortality or disease progression based on treatments received and other factors. Three have not yet been retrieved. 903 were excluded for other reasons: 115 for not enrolling the population of interest, 208 for not examining outcomes of interest, 287 because they enrolled less then 10 HIV positive women over 40, 82 were exclusively not in the U.S., 203 were not relevant to the topic, and 8 were not published. In the end, 32, 7, and 8 papers were eligible for the three areas of interest.

### Area 1 Studies Measuring the Impact of Strategies for Engaging Resources or Describing Barriers to Accessing Resources

Thirty-two papers were eligible in Area 1; 16 were studies that quantified the impact of strategies for engaging resources and 18 were about barriers to accessing resources (one paper was about both).^54-85^ Table 1 summarizes the characteristics of the women enrolled in these studies. Most studies were conducted in urban centers, such as New York, San Francisco, Atlanta, Boston, and Philadelphia, though a few focused on rural populations or examined differences between rural and urban populations. While all included studies were published after 2005, they analyzed populations enrolled as early as the mid-1990s. Studies included an average of 70 women (nine included more than 200 women).

Table 1 Characteristics of women in papers measuring the impact of strategies for engaging resources, or assessing barriers to engaging resources (Area 1)

Characteristic | Papers reporting information (% out of 32) | Median (25th, 75th) | Range
Publication year | 32 (100) | 2013 (2010, 2014) | 2006 to 2016
Number of included women (all ages) | 32 (100) | 70 (30, 157) | 15 to 1701
Enrollment start year | 24 (75) | 2006 (2002, 2010) | 1994 to 2014
Enrollment duration, years | 24 (75) | 2 (1, 4) | 1 to 6
Information on age
Women, proportion >40 years^*^ | 10 (31) | 79 (76, 100) | 48 to 100
Mean age, years | 24 (75) | 45 (43, 47) | 36 to 57
At or after menopause, % | 0 (0) | NA | NA
Diagnosed with HIV at older age, % | 0 (0) | NA | NA
Race/ethnicity
White, % | 15 (47) | 14 (8, 30) | 1 to 50
Black/African American, % | 28 (88) | 78 (59, 86) | 16 to 100
Latino/Hispanic, % | 18 (56) | 15 (10, 28) | 2 to 55
Asian, % | 0 (0) | NA | NA
Native American, % | 3 (9) | 7 (4, 9) | 4 to 9
Pacific Islander, % | 1 (3) | 7 (7, 7) | 7 to 7
Other, % | 12 (38) | 6 (3, 15) | 1 to 100
Other sociodemographic factors
With a social support circle, % | 7 (22) | 58 (47, 62) | 11 to 85
Married/with partner, % | 12 (38) | 20 (16, 30) | 12 to 73
Caring for a dependent, % | 7 (22) | 31 (24, 55) | 16 to 100
With annual income <$10,000, % | 15 (47) | 64 (50, 76) | 33 to 94
Undocumented immigrants, % | 1 (3) | 48 (48, 48) | 48 to 48
Unemployed, % | 13 (41) | 75 (68, 80) | 33 to 100
Have not finished high school, % | 22 (69) | 39 (32, 50) | 7 to 80
With history of incarceration, % | 1 (3) | 100 (100, 100) | 100 to 100
Experiencing violence, %^**^ | 2 (6) | 17 (5, 29) | 5 to 29
Using illegal substances, % | 8 (25) | 46 (27, 100) | 14 to 100
With mental health diagnoses, % | 7 (22) | 55 (38, 76) | 4 to 78
Insurance status
Without insurance, % | 5 (16) | 27 (9, 35) | 8 to 39
With public insurance, % | 7 (22) | 73 (61, 100) | 60 to 100
With private insurance, % | 5 (16) | 15 (5, 15) | 4 to 18
Gender identity and sexual orientation
Transgender women, % | 2 (6) | 50 (0, 100) | 0 to 100
Lesbian or bisexual women, % | 5 (16) | 11 (7, 17) | 0 to 33
Without sexual concurrency, % | 0 (0) | NA | NA

* Or older than another eligible age-cutoff;

** defined in both studies as “domestic violence” either current or in the past.

Results in Table 1 pertain to women of all ages, not only to those older than 40 years. Mean ages ranged between 36 and 57 years, and no study provided results in the elderly. No study reported the women's menopausal status or the age at which they were diagnosed with HIV.

Among the 28 studies that reported information on the race/ethnicity of participants, the median proportion of African American, Latino/Hispanic, and White women was 78, 15, and 14 percent, respectively. Three studies enrolled a small proportion of Native American women, and one included Pacific Islander women. No study reported enrolling Asian women.

In studies reporting such information, on average 20 percent of women reported having a spouse or partner, 58 percent perceived having adequate social support, and 31 percent cared for a dependent, but such information was provided in less than a third of the included studies. Among studies listing such information, the average proportion of women who had annual income less than approximately $10,000, were unemployed, had not finished high school, used illegal substances, or faced mental health challenges ranged between 31 and 75 percent. Only one or two studies reported on the proportion of women who were undocumented immigrants (1 study), experienced violence (2 studies), or had a history of incarceration (1 study).

The median reported in these papers was that 73 percent of women had some form of public insurance (Medicare or Medicaid), 15 percent had private insurance, and 27 percent had no insurance, but this information was reported in only five to seven studies.

Finally, the vast majority of studies did not explicitly report information on sex of women's sexual partners or gender self-identification. For example, no study reported the proportion of women who have more than one concurrent sexual partner, four studies included women who were identified in the study as lesbian or bisexual (ranging from 6.6% to 33% of the study population), and one study enrolled only transgender women.

#### Studies Measuring the Impact of Strategies for Engaging Resources

Sixteen papers on 13 unique studies measured the impact of engaging with various services or with programs bundling several services (Table 2). ^54, 70-82, 84^ Eight RCTs (described in 10 papers^70-76, 79, 80, 84^) randomized between 30 and 184 participants to receive either a specific program or an alternative (placebo or different program). The programs included a health promotion intervention aimed at reducing cardiovascular disease risk, a motivational intervention for quitting smoking, three interventions aimed at reducing alcohol consumption and/or risky sexual behavior, a writing intervention to address perceived HIV stigma, and Structural Ecosystems Therapy to promote healthy relationships within and outside the family and address relapse prevention and medication adherence. Of these eight programs, two had a medical component, seven had a psychosocial component, none had case management, six had an educational component, and four had an STD prevention component (Table 2).

Table 2 Characteristics of studies of strategies to promote women's engagement with resources

Author (year) | Study location | Women (% who are >40y) | Mean age | Intervention or comparison | Intervention objective | Medical Component | Psychosocial Component | Case management Component | Health education Component | STD prevention Component | Outcomes measured
Randomized controlled trials
Abel (2006)^84^ | Texas | 44 | 44 | Writing intervention | Reducing perceived HIV stigma | No | Yes | No | No | No | Perceived HIV stigma
Chander (2015)^79^ | Baltimore, MD | 148 (NS) | 44 | Brief alcohol intervention | Reducing drinking; reducing risky sexual behavior | No | Yes | No | Yes | Yes | Alcohol consumption, sexual behavior, HIV outcomes
Echenique (2013)^80^ | Miami | 106 (100) | NS | Project ROADMAP, Reeducating Older Adults in Maintaining AIDS Prevention | Reducing risky sexual behavior | No | Yes | No | Yes | Yes | Sexual risk behavior/HIV knowledge
Feaster (2010)^71,*^ | Florida | 156 (NS) | 36 | Structural Ecosystems Therapy vs usual care | Promote healthy family and social relationships | No | Yes | No | Yes | No | Self-reported medication adherence
Feaster (2010)^72,*^ | Florida | 126 (NS) | 43 | Structural Ecosystems Therapy vs usual care | Address relapse prevention and medication adherence | No | Yes | No | Yes | No | Self-reported substance abuse, medication adherence
Mitrani (2012)^74,*^ | Florida | 126 (NS) | 43 | Structural Ecosystems Therapy vs usual care | Address relapse prevention and medication adherence | No | Yes | No | Yes | No | Psychological Distress and Drug Abstinence (Brief Symptom Inventory, self-reported illicit drug use)
Teti (2010)^70^ | Philadelphia (PA) | 184 (NS) | 40 | Protect and Respect vs educational information | Decrease risky sexual practices | No | Yes | No | Yes | Yes | Self-reported disclosure of HIV status to partners; condom use
El-Bassel (2011)^73^ | Atlanta (GA), LA (CA), NYC (NY), Philadelphia (PA) | 158 (NS) | NS | Risk reduction intervention vs health promotion intervention | Influence behaviors linked to chronic disease, including diet and exercise | Yes | No | No | Yes | Yes | Mammography screening
DeMarco (2013)^76^ | Boston (MA) | 110 (100) | NS | Sistah Powah Structured Writing Intervention vs attention control | Increased use of cognitive behavioral self-help programs, regular medical and HIV care, psychosocial support | No | Yes | No | No | No | Adherence to health care: keeping appointments, risky sexual behavior, testing for comorbidities, needle care, lifestyle factors
Manuel (2013)^75^ | San Francisco (CA) | 30 (NS) | 49 | Motivational Interviewing vs prescribed advice | Smoking cessation | Yes | Yes | No | Yes | No | Smoking intensity and cessation
Observational studies
Cocohoba (2013)^54^ | San Francisco (CA) | 17 (NS) | NS | Pharmacy intervention | Promote ART adherence | Yes | No | Yes | Yes | No | ART adherence
Dutcher (2011)^77^ | US urban rural regions | 15 (NS) | NS | Peer support | Social support | No | Yes | No | Yes | Yes | Care adherence/housing status
Kupprat (2009)^81^ | New York | 46 (NS) | 47 | Social support substance use and mental health services | Substance abuse treatment, mental health services, case manager, support groups | Yes | Yes | Yes | No | No | Attendance, reception of therapy
Proeschold-Bell (2016)^82^ | North Carolina | 76 (NS) | 46.5 | Substance Use Treatment Integrated Care from Social Workers and HIV Medical Providers | Substance use treatment | Yes | Yes | No | Yes | No | Alcohol/drug use
Sullivan (2015)^78^ | Chapel Hill (NC) | 21 (NS) | 45 | Guide to Healing Program | Link HIV infected people to care | No | No | Yes | Yes | No | Self-reported ART adherence and medication management; accessing resources, including medication assistance, and community based services
Weiss (2015)^85^ | Miami (FL), NYC (NY), (NJ) | 364 (NS) | 45 | SMART/EST Women's Program | Enhance quality of life | No | Yes | No | No | No | Depression, medication adherence

* These papers refer to the same study.

LA: Los Angeles; NYC: New York City; SMART/EST: Stress Management And Relaxation Training/Emotional Supportive Therapy.

The outcomes measured include, but are not limited to, adherence to heath care or medication, undergoing cancer screening, smoking cessation, experiencing psychological distress or HIV-related stigma, substance abuse, sexual behavior, and disclosure of HIV status to potential sexual partners.

An additional six studies assessed the impact of engaging with programs in a qualitative fashion. Three were based on interviews of 15 to 21 participants^54, 77, 78^, a fourth examined a cohort of 364 participants in a stress-management intervention,^85^ and two examined programs aimed at reducing substance use in 46 and 76 participants, respectively.^81, 82^ These programs included a joint venture with pharmacies to promote ART adherence, a peer-support program to provide social support; a program to link HIV positive women to care; a social-support program for substance abuse; a multifaceted program that integrated patient navigation, mental health counseling, and support groups; and the largest study evaluated a program designed to enhance quality of life, thereby reducing depression and increasing medication adherence. Of these six programs, two had a medical component, four had a psychosocial component, three had case management, four had an educational component, and one had an STD prevention component (Table 2).

#### Studies of Barriers in Accessing Resources

Eighteen observational studies^54-69, 81, 83^ evaluated barriers to care in populations ranging from 17 to 1701 women. Almost all of the barriers studied involved engaging or retention in HIV care, though three studies exclusively assessed outcomes not related to HIV, including cancer screening (1 study), accessing program services online (1 study), and using the internet (1 study) (Table 3). Of the 14 studies that evaluated barriers to engaging or retention in care, the types of barriers were sociodemographic in 12, cultural in 6, psychosocial in 11, related to experience with incarceration in one, medical in 12, and mental history in 6. Two studies looked at barriers to cancer screening that were sociodemographic, psychosocial, and medical in nature. ^59, 66^ One study evaluated psychosocial and medical barriers to adherence to treatment in the context of a pharmacy program.^54^ Two studies, both by Blackstock et al., evaluated barriers to using the Internet, either in general or to access social support. These studies identified barriers from nearly every aspect (sociodemographic, cultural, psychosocial, medical history, and mental history),^55, 57^ which may inform the design of Web-based programs, as well as strategies to enhance their uptake and use.

Table 3 Characteristics of studies of barriers to accessing resources

Author (year) | Study location | Women (%>40y) | Mean age | Barriers to… | Person-level modifiers examined | | | | | | System-level (including provider-related) modifiers examined
Author (year) | Study location | Women (%>40y) | Mean age | Barriers to… | Sociodemographic | Cultural | Psychosocial | Exp. w/ incarceration | Medical history | Mental history | System-level (including provider-related) modifiers examined
Studies of barriers to engaging or remaining in care
Burke-Miller (2006)^58^ | Various urban^*^ | 1701 (48) | NS | Engaging in care | Yes | Yes | Yes | No | Yes | Yes | None
Blackstock (2015)^56^ | Various urban^**^ | 748 (NS) | 42 | Engaging in care | Yes | No | Yes | No | Yes | Yes | Transportation
Williams (2013)^69^ | Various urban^***^ | 350 (NS) | 41 | Engaging in care | Yes | No | Yes | Yes | Yes | Yes | Intensity of care services received in jail
Tello (2010)^66^ | Baltimore (MD) | 200 (76) | 46 | Engaging in care; cancer screening | Yes | No | Yes | No | Yes | No | Transportation, relationship with provider
Toth (2013)^67^ | (NC) | 164 (NS) | 46 | Engaging in care | Yes | Yes | Yes | No | Yes | Yes | Transportation, financial, other logistical
Sevelius (2014)^64^ | San Francisco (CA) | 58 (81) | NS | Engaging in care | Yes | Yes | Yes | No | Yes | No | Provider/staff cultural competence, integrated transgender and /HIV care, confidentiality
Stevens (2009)^65^ | (WI) | 55 (NS) | 41 | Engaging in care | No | No | No | No | No | No | Insurance, transportation, financial, provider turnover
Fletcher (2014)^59^ | Houston (TX) | 33 (NS) | 51 | Cervical cancer screening | No | No | Yes | No | Yes | No | Transportation, wait times, scheduling
Quinlivan (2013)^63^ | (NC) | 30 (67) | 45 | Engaging in care | Yes | Yes | Yes | No | Yes | Yes | Navigating labs, transportation and parking, relationship with providers
Vyavaharkar (2008)^68^ | (SC) | 22 (NS) | 44 | Engaging in care | Yes | Yes | Yes | No | Yes | No | Relationship with provider
Pivnick (2010)^62^ | Bronx (NY) | 21 (NS) | 48 | Engaging in care | Yes | Yes | Yes | No | Yes | No | None
McDoom (2015)^61^ | Boston (MA) | 20 (100) | 57 | Engaging in care | No | No | Yes | No | No | No | Relationship with provider
Kempf (2010)^60^ | Alabama (AL) | 39 (77) | 46 | Retention in care | Yes | No | Yes | No | Yes | No | Transportation, clinic hours, flexible scheduling
Kupprat 2009^81^ | New York | 46 (NS) | 47 | Engaging in care | Yes | No | No | No | Yes | Yes | Unclear
Sarnquist 2011^83^ | California | 64 (49) | NS | Engaging in care | Yes | No | No | No | Yes | No | Transportation, navigating healthcare system
Studies of barriers to other goals
Blackstock (2015)^55^ | Bronx (NY) | 103 (100) | 50 | Using the Web | Yes | Yes | Yes | No | Yes | Yes | Place of medical care (clinic, private PCP vs healthcare for homeless, methadone clinic, visiting PCP)
Blackstock (2015)^57^ | Bronx (NY) | 27 (NS) | 49 | Accessing Web-based social support | Yes | Yes | Yes | No | Yes | No | None
Cocohoba (2013)^54^ | San Francisco (CA) | 17 (NS) | NS | Adhering to ART | No | No | Yes | No | Yes | No | Privacy, pharmacy location, presence of drug-seeking or intoxicated pharmacy patrons, relationship with provider

* NYC (NY), Washington (DC), Chicago (IL), LA & San Francisco (CA).

** Brooklyn (NY), Chicago (IL), LA (CA), Miami (FL), San Antonio (TX), Springfield (MA), Alabama (AL), (NC), Longview (TX)

*** Atlanta (GA), Chester (PA), Chicago (IL), Cleveland (OH), Columbia (SC), New Haven (CT), New York city (NY), Philadelphia (PA), Providence (RI); Springfield (MA)

ART: antiretroviral therapy; NS: not stated.

The most commonly cited system- or provider-level barriers were lack of transportation and logistical challenges (including navigating facilities, wait times, clinic hours, and insurance-related bureaucracy) (6 studies), and relationships with providers (4 studies).

### Area 2 Studies Measuring the Effect of Insurance on Outcomes

Seven eligible papers evaluated the overall effect of insurance on outcomes (Table 4). Because of the overlap in the included studies, the study and population characteristics in Table 4 are qualitatively similar to those in Table 1. The seven studies report no information on several characteristics of interest, including proportion of women with a spouse or partner who is available; with history of incarceration; who are undocumented immigrants; who identify as lesbian, bisexual or transgender; or who have multiple concurrent sexual partners. Six of these are included among the studies of barriers described in the previous section.^54-56, 58, 65, 67^ These six studies reported the impact of insurance source (e.g. Medicaid, private, any, or none) on engagement with or retention in care, satisfaction with care, antiretroviral adherence, and Internet use. The seventh study evaluated the association between insurance and successful management of major depressive disorder.^86^.

Table 4 Characteristics of women in papers measuring the impact of insurance on outcomes (Area 2)

Characteristic | Papers reporting information (% out of 7) | Median (25th, 75th) | Range
Publication year | 7 (100) | 2013 (2009, 2015) | 2006 to 2015
Number of included women (all ages) | 7 (100) | 164 (55, 748) | 17 to 1701
Enrollment start year | 6 (86) | 2005 (1994, 2010) | 1994 to 2014
Enrollment duration, years | 6 (86) | 2 (2, 4) | 1 to 4
Information on age
Women, proportion >40 years^*^ | 2 (29) | 74 (48, 100) | 48 to 100
Mean age, years | 5 (71) | 43 (42, 46) | 41 to 50
At or after menopause, % | 0 (0) | NA | NA
Diagnosed with HIV at older age, % | 0 (0) | NA | NA
Race/ethnicity
White, % | 5 (71) | 18 (11, 32) | 1 to 36
Black/African American, % | 7 (100) | 60 (55, 68) | 53 to 85
Latino/Hispanic, % | 6 (86) | 26 (7, 30) | 3 to 35
Asian, % | 0 (0) | NA | NA
Native American, % | 2 (29) | 6 (4, 9) | 4 to 9
Pacific Islander, % | 0 (0) | NA | NA
Other, % | 3 (43) | 5 (2, 6) | 2 to 6
Other sociodemographic factors
With a social support circle, % | 0 (0) | NA | NA
Married/with partner, % | 3 (43) | 16 (16, 34) | 16 to 34
Caring for a dependent, % | 2 (29) | 27 (24, 31) | 24 to 31
With annual income <$10,000, % | 3 (43) | 63 (50, 73) | 50 to 73
Undocumented immigrants, % | 0 (0) | NA | NA
Unemployed, % | 3 (43) | 70 (58, 78) | 58 to 78
Have not finished high school, % | 5 (71) | 35 (35, 37) | 17 to 47
With history of incarceration, % | 0 (0) | NA | NA
Experiencing violence, % | 1 (14) | 29 (29, 29) | 29 to 29
Using illegal substances, % | 3 (43) | 28 (14, 38) | 14 to 38
With mental health diagnoses, % | 5 (71) | 51 (38, 55) | 4 to 100
Insurance status
Without insurance, % | 4 (57) | 11 (8, 20) | 8 to 27
With public insurance, % | 2 (29) | 67 (61, 73) | 61 to 73
With private insurance, % | 3 (43) | 15 (15, 18) | 15 to 18
Gender identity and sexual orientation
Transgender women, % | 0 (0) | NA | NA
Lesbian or bisexual women, % | 0 (0) | NA | NA
Without sexual concurrency, % | 0 (0) | NA | NA

* Or older than another eligible age-cutoff;

** defined as “domestic violence” either current or in the past.

In no study did more than 18 percent of the women have private insurance. Where it was reported, between 60 and 100 percent of women had public insurance, and between 7 and 35 percent had no insurance. In all studies, insurance type was one of several predictors in a regression model. These studies were not designed to estimate the causal effect of insurance (relying on simple regression analyses instead of causally explicit methods, such as propensity scores, instrumental variables, or marginal structural modeling), and each study considered and controlled for different variables.

### Area 3 Studies on the Diagnosis or Management of Comorbidity, or on Predictive Models

Eight papers (seven studies), with sample sizes between 46 and 1234 participants were deemed eligible (Table 5). ^72, 74, 79, 86-90^ Because of the overlap in the included studies, the study and population characteristics in Table 5 are qualitatively similar to those in Table 1. The eight publications report no information on several characteristics of interest, including proportion of women with a spouse or partner who is available, undocumented immigrants, history of incarceration, women who identify as lesbian, bisexual, or transgender or have multiple concurrent sexual partners. No study informed on diagnosis of or screening for comorbidities among older women living with HIV/AIDS; six reported information on the management of comorbidities; and two reported on predictive models of HIV progression or overall mortality in the presence of comorbid conditions.

Table 5 Characteristics of women in papers on the diagnosis or management of comorbidity, or of predictive models (Area 3)

Characteristic | Papers reporting information (% out of 8) | Median (25th, 75th) | Range
Publication year | 8 (100) | 2010 (2008, 2013) | 2006 to 2015
Number of included women (all ages) | 8 (100) | 700 (137, 1101) | 126 to 1234
Enrollment start year | 8 (100) | 1996 (1995, 1998) | 1994 to 2006
Enrollment duration, years | 8 (100) | 4 (3, 8) | 2 to 10
Information on age | 0 (0) | NA | NA
Women, proportion >40 years^*^ | 7 (88) | 43 (38, 43) | 36 to 44
Mean age, years | 0 (0) | NA | NA
At or after menopause, % | 0 (0) | NA | NA
Diagnosed with HIV at older age, % | 4 (50) | 14 (13, 28) | 11 to 40
Race/ethnicity | 7 (88) | 79 (53, 84) | 35 to 86
White, % | 5 (62) | 15 (12, 30) | 12 to 30
Black/African American, % | 1 (12) | 1 (1, 1) | 1 to 1
Latino/Hispanic, % | 0 (0) | NA | NA
Asian, % | 0 (0) | NA | NA
Native American, % | 2 (25) | 13 (9, 16) | 9 to 16
Pacific Islander, % | 3 (38) | 58 (33, 58) | 33 to 58
Other, % | 0 (0) | NA | NA
Other sociodemographic factors | 0 (0) | NA | NA
With a social support circle, % | 4 (50) | 50 (50, 55) | 50 to 60
Married/with partner, % | 0 (0) | NA | NA
Caring for a dependent, % | 2 (25) | 19 (5, 33) | 5 to 33
With annual income <$10,000, % | 4 (50) | 57 (38, 75) | 35 to 75
Undocumented immigrants, % | 0 (0) | NA | NA
Unemployed, % | 0 (0) | NA | NA
Have not finished high school, % | 4 (50) | 100 (80, 100) | 59 to 100
With history of incarceration, % | 3 (38) | 100 (32, 100) | 32 to 100
Experiencing violence, % | 1 (12) | 14 (14, 14) | 14 to 14
Using illegal substances, % | 1 (12) | 74 (74, 74) | 74 to 74
With mental health diagnoses, % | 0 (0) | NA | NA
Insurance status | 0 (0) | NA | NA
Without insurance, % | 0 (0) | NA | NA
With public insurance, % | 0 (0) | NA | NA
With private insurance, % | 8 (100) | 2010 (2008, 2013) | 2006 to 2015
Gender identity and sexual orientation | 8 (100) | 700 (137, 1101) | 126 to 1234
Transgender women, % | 8 (100) | 1996 (1995, 1998) | 1994 to 2006
Lesbian or bisexual women, % | 8 (100) | 4 (3, 8) | 2 to 10
Without sexual concurrency, % | 0 (0) | NA | NA

* Or older than another eligible age-cutoff

Of the six studies that included information on management of comorbidities, two pertained to depression, three to alcohol and other substance abuse, and one to cardiovascular disease.^72, 74, 79, 86-89^ Of the two studies on management of depression, one examined whether psychopharmacologic and psychotherapeutic treatment of depressed HIV-women met standards defined in the best practice literature and assessed predictors of standard-concordant care,^86^ and the other examined whether antidepressant use by HIV-positive patients results in better employment rates.^87^ Among the three studies on management of drug and alcohol abuse, one evaluated a family-based intervention (Structural Ecosystems Therapy) compared with a psychoeducational intervention for seropositive women who recover from drug abuse.^72, 74^ Another informed on associations between heavy alcohol consumption and antiretroviral treatment initiation and mortality,^88^ and a third evaluated a brief alcohol intervention in seropositive women with heavy drinking problems.^79^ Finally, a cohort study informed on rates of acute myocardial infarction among HIV-positive patients with cardiovascular risk factors.^89^

Two eligible cohort studies described models predicting HIV progression or overall mortality among older women living with HIV/AIDS who also have comorbidities.^88-90^ The first predicted clinical progression HIV disease based on illicit drug use and various sociodemographic factors (such as age, race, and sexual history) and medical history factors (such as antiretroviral use, CD4 cell counts, and CDC category of HIV disease at baseline).^90^ Another predicted all-cause mortality among older women living with HIV/AIDS who also have substance and alcohol abuse problems based on sociodemographic factors (age and race), medical history factors (including using various drugs, alcohol and tobacco, having hepatitis C, prior antiretroviral therapy, CD4 counts, and viral load), and mental health factors (including a history of depression, anxiety, or psychosis).^88^

## Illustration of Salient Issues

As described in the Methods section, to better appreciate the issues for women over 40 living with HIV/AIDS that might be missed in a literature review, we interviewed a social worker at the Immunology Clinic at the Brown-affiliated Miriam Hospital. This clinic is a well-organized, nationally recognized center that provides integrated general medical and specialist care, as well as mental health and social support to people living with HIV/AIDS. The following factually accurate vignettes are summarized from the descriptions given to us by the Miriam Hospital social worker. They emphasize the need for case management and individualized care and illustrate some of the challenges faced by older women who live with HIV/AIDS.

### Four Vignettes

#### K.P

K.P. is an 85-year-old woman diagnosed with AIDS in her 80s. She had been generally healthy but started losing weight, with night sweats, poor appetite and easy fatigue. She saw multiple physicians, but no clear diagnosis was made. In 2013, she was admitted to the Oncology service for a full work up for a malignancy. She was wheelchair bound and extremely weak. Work up did not show any malignancy or rheumatologic disease. An intern suggested an HIV test, since all other tests were unremarkable. The HIV test came back positive, and her CD4 count was 10. No one thought to test her, as no one thought a woman in her 80s would be sexually active. She was started on antiretroviral therapy, and responded very well. She continues to be seen in clinic with good HIV control. She has gained back weight and is very active and ambulant.

The risk of HIV infection in older and elderly women is often underappreciated, perhaps because of wrong assumptions about women's sex life in older age, leading to underdiagnosis and unnecessary suffering.

#### B.T

B.T. is a 65-year-old woman diagnosed with HIV in 1989, which probably resulted from injection drug use. She was started on monotherapy at the time and has been on several regimens over the years, as newer medication classes have become available. She has suffered many treatment-related side effects, and for a time did not want to take her HIV medications. She tolerates newer medications well, takes them, and her HIV infection is now under control, with very low CD4 counts. She is a chronic smoker, has chronic obstructive pulmonary disease, pulmonary hypertension, and hepatitis C. She has not used drugs for many years, but has “survivor's guilt” as she feels she should be dead like all of her contemporaries who shared needles with her and also contracted HIV. Being the only one alive among her group depresses her gravely, even though she is medically well.

Women like B.T., who are doing well medically and do not face such basic needs as housing, food security, or insurance coverage can still struggle emotionally and socially. Challenges are magnified for women who do not have peer, community, or other social support.

#### C.W

C.W. is a 50-year-old woman, diagnosed with HIV 18 years ago, in 1998. She regularly misses clinic appointments and does not regularly take her HIV medications, because she faces substance abuse, mental health, family, and social issues. She has never had good HIV control, with a consistently low CD4 count and an always-detectable viral load. She has been in rehabilitation many times for substance abuse, but always relapsed. She has been in jail multiple times. She tried a methadone program but was discharged, due to continued use of cocaine and heroin. She was lost to follow up for three years before resurfacing in clinic in 2015. She says that she had no time to take care of herself, as a result of family problems: her older son was recently convicted for sex trafficking and sentenced to 10 years in prison, and her younger son has been detained in a juvenile facility for selling drugs.

Women like C.W. may face substance abuse, mental health, and family and social challenges that are so major, disorganizing, and detrimental that they take precedence over HIV-related medical care.

#### M.W

M.W. is a 40-year-old transgender woman, who first transitioned to a girl with the aid of hormones at age 15. She contracted HIV 10 years ago, and is currently on treatment with good disease control. She had silicone injections for breast augmentation by “someone in a hotel room” and developed recurrent mastitis and severe scarring. She has renal failure and has been on dialysis for 8 years. She developed compartment syndrome from fistula infiltration, which left her with healing scars. She also has multiple catheter related scars on her chest. She has hypertension, hepatitis C, and recurrent moderate major depressive disorder. For the last several years she has avoided living as a woman, because she is seeking approval from her adopted family and living in environments where she feels stigmatized, and because the scars on her body from medical procedures affect her body image. She acknowledges that her avoidance of living as a woman has led her to not take as good care of herself as she should.

M.W.'s battles with depression, chronic disease, stigma, and lack of social support have had major adverse impact on her well-being and adherence to HIV and other medical care over the years, although she now seems to be getting the care she needs to control the HIV. Her need for social support and security means that she is no longer living as a women. Transgender women can easily fall through the current highly fragmented system of care, much like M.W. did during several periods of her life.

## Web-Survey of Available Resources for People Living with HIV/AIDS in Six States

It is unlikely that the published literature provides a credible high level overview of the number and type of resources available today in the U.S. for people who live with HIV, and by extension, for older women who live with HIV/AIDS. The Key Informants, our technical expert, and the social worker who helped us identify the above-listed vignettes, all suggested that resources for HIV patients are not well integrated. It is not clear how most patients are linked to HIV care resources, but it is likely that it comes through a combination of word of mouth referrals from HIV providers, and various community outreach programs.

We provide a high-level overview of the type and number of resources that are available and readily identified through focused and limited searches of the Internet in a purposeful sample of six states. We emulate a Web-savvy person (e.g., a woman living with HIV/AIDS, her provider, or her case manager), who does not have access to a provider referral network and is looking to identify resources for older women who live with HIV/AIDS in Rhode Island, Alabama, Mississippi, New York, Texas, and California. In addition, we show what resources are available using the tools at locator.aids.gov, which provides a graphical interface for locating resources throughout the U.S. The idea is not to suggest that women who live with HIV/AIDS should search the Internet to find resources; it is well appreciated that too many barriers exist for that to be effective.^55^ Instead, we aim to outline information on the density of resources that exist in the six states and to provide high-level empirical data.

The exposition is as follows: Table 6 provides information about the demographics of the HIV positive populations in the six states, obtained from the CDC and the states' Departments of Health. No data are readily available for most of the characteristics of interest (i.e., for the information on age, race, socioeconomic data, insurance status and sexual orientation in the rows of Table 1). Therefore, our ability to describe the population in these six states (and we suspect in other U.S. states) even at a basic level is hampered by lack of information.

Table 6 Characteristics of the people living with HIV/AIDS in the six states and across the U.S.

Characteristic | US | Rhode Island (State sources)^*^ | New York | Alabama | Mississippi | Texas | California
General information
Number of people | 316 million | 1.1 million | 19.7 million | 4.8 million | 3 million | 26.4 million | 38.3 million
Number of women | 160 million | 542 thousand | 10.1 million | 2.5 million | 1.5 million | 13.3 million | 19.3 million
Number of women over 40y | 71 million | 282 thousand | 5.0 million | 1.2 million | 732 thousand | 5.8 million | 8.9 million
Number of women with HIV (percentage who are over 40 years) | 225612 (NR) | NR (NR) | 39209 (NR) | 3848 (NR) | 3156 (NR) | 17350 (61) | 14071 (NR)
Incident HIV cases in 2013 among women (percentage over 40 years) | 8328 (NR) | 16 (NR) | 742 (52) | 146 (35) | 93 (16) | 823 (39) | NR
Racial information, among women over 40 years ^ a ^ | NR | NR | NR | NR | NR | NR | NR
Other sociodemographic factors, among women over 40 years ^ b ^ | NR | NR | NR | NR | NR | NR | NR
Insurance status, among women over 40 years ^ c ^ | NR | NR | NR | NR | NR | NR | NR
Gender identity and sexual orientation, among women over 40 years ^ d ^ | NR | NR | NR | NR | NR | NR | NR
Medicaid expansion (yes/no) | NA | Yes | Yes | No | No | No | Yes

* Information on RI from the Immunology Clinic, which sees approximately 85% of the HIV population in the State in Table 7.

a Percentages for White; Black/African American; Latino/Hispanic; Asian; Native American; Pacific Islander; Other

b Percentages with a social support circle; married/with partner; caring for a dependent; with annual income <$10,000; undocumented immigrants; unemployed; have not finished high school; with history of incarceration; experiencing violence; using illegal substances; with a mental health diagnosis

c Percentages without insurance; with public insurance; with private insurance

d Percentages for transgender women; lesbian or bisexual women; with sexual concurrency

Table 7 Characteristics of the women living with HIV/AIDS who are older than 40 years in the Immunology Clinic at the Miriam Hospital in RI

Characteristic | Number | Percentage among women over 40 years
Age information
Over 40 years | 359 | 100
40-55 years | 247 | 69
56-70 years | 98 | 27
71-99 years | 14 | 4
Race/ethnicity
Latina/Hispanic | 115 | 32
All other | 244 | 68
Place of birth
U.S. born | 173 | 48
Foreign bon | 153 | 43
Unknown | 33 | 9
Transmission category
Sexual | 239 | 67
Injection Drug User | 72 | 20
Receipt of Blood Transfusion | 3 | <1
Others/Unknown | 45 | 13
Marital/partnership status
Divorced | 26 | 7
Married | 85 | 24
Partnered | 24 | 7
Single | 181 | 50
Unknown | 17 | 4
Widow | 28 | 8
Highest educational attainment
No schooling at all | 11 | 3
Grade school | 37 | 10
Some high school | 50 | 14
High school | 37 | 10
Some college | 35 | 10
College | 20 | 6
Vocational or technical | 11 | 3
Unknown | 160 | 44
Other sociodemographics ^ a ^ | ND | ND
Gender identity and sexual orientation ^ b ^ | ND | ND

a Percentages with a social support circle; caring for a dependent; with annual income <$10,000; undocumented immigrants; unemployed; with history of incarceration; experiencing violence; using illegal substances; with a mental health diagnosis

b Percentages for transgender women; lesbian or bisexual women; with sexual concurrency

To provide some more context, for Rhode Island, we obtained information on some of these factors from the database of the Immunology Clinic at the Miriam Hospital, which covers an estimated 85% of the state's HIV population. This information is listed in Table 7, for variables that are analogous, but not identical, to the ones in Table 1. Briefly, among the 359 women who are older than 40 years and live with HIV the majority (69 percent) is in the 40-55 year old bracket, and 43 percent are foreign-born. Most (67 percent) have ben infected through sexual relationships, and 20 percent are likely to have been infected through injection drug use. Half report being currently single. The highest educational attainment is unknown in 44 percent, and 27 percent has not completed high school. This detailed information was not practically available from the other states, or at the U.S. level.

Table 8 shows the number of centers offering services related to HIV testing, housing, general health, mental health, substance abuse and family planning, and the number of Ryan White HIV Care-funded programs located within a 20-mile radius from the center of a large, a median, and a small city in each of the six states, as found through the Web site locator.aids.gov. In the text we also list, for each state, pertinent information gleaned from the Web sites of the Departments of Health and from targeted general Internet searches. Figures 3, 4, and 5 plot the density of each type of resource in the largest, median, and smallest city in the six states per 1000 inhabitants (panel a) or normalized by the total number of people leaving with HIV/AIDS in the state (panel b).

Table 8 Number of resources available in each the largest, median and smallest city in each state

State, Cities | HIV Testing | Housing Assistance | Health Centers | Ryan White HIV Care | Mental Health | Substance Abuse | Family Planning
Rhode Island
Providence | 16 | 6 | 38 | 3 | 69 | 57 | 19
Burrillville | 20 | 5 | 30 | 3 | 48 | 44 | 15
Charlestown | 3 | 0 | 4 | 3 | 5 | 9 | 2
New York
New York City | 329 | 20 | 309 | 51 | 253 | 582 | 108
Rochester | 17 | 5 | 28 | 3 | 21 | 34 | 4
Little Falls | 1 | 0 | 5 | 5 | 6 | 8 | 1
Texas
Houston | 44 | 14 | 54 | 9 | 21 | 62 | 12
Amarillo | 7 | 1 | 3 | 3 | 4 | 4 | 1
Del Rio | 2 | 0 | 3 | 4 | 1 | 0 | 0
California
Los Angeles | 135 | 20 | 284 | 22 | 152 | 243 | 93
Escondido | 23 | 3 | 33 | 3 | 19 | 33 | 21
Imperial | 4 | 1 | 6 | 5 | 1 | 6 | 0
Mississippi
Jackson | 10 | 3 | 17 | 3 | 17 | 10 | 3
Tupelo | 5 | 0 | 3 | 11 | 5 | 2 | 4
Mound Bayou | 2 | 0 | 4 | 3 | 1 | 2 | 3
Alabama
Birmingham | 14 | 2 | 6 | 4 | 21 | 17 | 4
Dothan | 4 | 0 | 3 | 5 | 4 | 5 | 1
Demopolis | 3 | 0 | 4 | 6 | 5 | 1 | 1

Information for each city from https://locator.aids.gov/; the counts pertain to resources that are within 20 miles of the corresponding city or town center. Last accessed January 15, 2016. Cities in each state (or part of state) are ordered from largest to smallest in terms of population reported in the most recent census.

Figure 3 Density of facilities in a large city in each state (Table 8)

These two figures include a series of histograms that show the density of resources in a large city in each state. Alabama, California, Mississippi, New York, Rhode Island, and Texas are listed on the x axis, and density on the y axis. Figure 3a shows the density by population (per 1000 people) of the city. For HIV testing, all states had a density between 0.2 and 1.0, with Texas the lowest, and Rhode Island the highest. For housing assistance, all had a density between 0.01 and 0.2, with the exception of Rhode Island, whose density was close to 0.3. For health centers, all states were below 0.1, except Rhode Island, which was at 0.2. For Ryan White programs, Alabama, Mississippi, and Rhode Island were between 0.15 and 0.2, while California, New York, and Texas were around 0.005. For mental health centers and substance abuse centers, all states were below 0.1, except Rhode Island, which was close to 0.4. For family planning centers, Alabama and Texas had none, New York has almost none, California and Mississippi had less than 0.02, and Rhode Island had over 0.8. Figure 3b shows the density by population (per 1000 people) with HIV in the state. For HIV testing, most states had a density between 0 and 2, with Rhode Island the highest at over 6, and New York the next highest at just over 2. For housing assistance, all had very low, with the exception of Rhode Island, whose density was close to 3. For health centers, all states were below 5, except Rhode Island, which was at approximately 15. For Ryan White programs, Alabama, California, Mississippi, and New York were below 0.5, with Texas the lowest; again Rhode Island was the outlier at over 1.5. For mental health centers and substance abuse centers, all states were very low, except Rhode Island, which was over 25 for both. For family planning centers, again all states were very low, except Rhode Island, which was just above 8.

Figure 4 Density of facilities per 1000 inhabitants in a median city in each state (Table 8)

These two figures include a series of histograms that show the density of resources in a median city in each state. Alabama, California, Mississippi, New York, Rhode Island, and Texas are listed on the x axis, and density on the y axis. Figure 4a shows the density by population (per 1000 people) of the city. For HIV testing, housing assistance, health centers, mental health centers, and substance abuse centers, all states had very low densities, except Rhode Island, which was much higer. For Ryan White programs, Mississippi and Rhode Island were between 0.15 and 0.3, while California, New York, and Texas were around 0.005; Alabama was in the middle at just under 0.1. For family planning centers, all states were below 0.02, except Rhode Island, which was just above 0.1. Figure 4b shows the density by population (per 1000 people) with HIV in the state. For HIV testing, housing assistance, health centers, mental health centers, substance abuse centers, and family planning centers, all states were very low, except Rhode Island, which was much higher. For Ryan White programs, Rhode Island had the greatest density (just under 1.5), then Mississippi (around 1.0), then Alabama (just under 0.5). California, New York, and Texas had very few.

Figure 5 Density of facilities per 1000 inhabitants in a small city in each state (Table 8)

These two figures include a series of histograms that show the density of resources in a small city in each state. Alabama, California, Mississippi, New York, Rhode Island, and Texas are listed on the x axis, and density on the y axis. Figure 5a shows the density by population (per 1000 people) of the city. For HIV testing, health centers, and Ryan White programs, all states had a density below 0.5, with Texas, California, and New York close to 0, and Rhode Island the highest at around 1.5. For housing assistance, only Rhode Island was above 0, at 0.008. For mental health centers Rhode Island was the highest at 2, followed by Alabama at 0.5. The other states were close to 0. Similarly, for substance abuse centers, all states were close to 0, except Rhode Island, which was close to 4. For family planning centers, California, New York, and Texas had none, Alabama has almost none, Mississippi had about 0.03, and Rhode Island had over 0.8. Figure 5b shows the density by population (per 1000 people) with HIV in the state. For HIV testing, most states had a density between 0 and 2, with Rhode Island the highest at over 6, and New York the next highest at just over 2. For housing assistance, all had very low, with the exception of Rhode Island, whose density was close to 3. For health centers, all states were below 5, except Rhode Island, which was at approximately 15. For Ryan White programs, Alabama, California, Mississippi, and New York were below 0.5, with Texas the lowest; again Rhode Island was the outlier at over 1.5. For mental health centers and substance abuse centers, all states were very low, except Rhode Island, which was over 25 for both. For family planning centers, again all states were very low, except Rhode Island, which was just above 8.

While there is variation across the six states in the number of facilities per 1000 inhabitants, it appears that, at least in the largest city in each state the density of facilities is comparable (Figure 3). Across the states, Texas appears to have the lower density of each type of facility; however it is the largest state. When it comes to the median and smallest city in each state however, the variation is more notable, with Rhode Island being an outlier (Figures 4 and 5). Further, the median and smallest cities do not have at least one facility of each kind (Table 8; Figures 4 and 5).

### Rhode Island

A Google search for Rhode Island and HIV or AIDS yielded the Web site for the State of Rhode Island Department of Health (http://www.health.ri.gov/diseases/hivaids/). This site includes educational information, publications, programs, regulations, and partners. There is an application for the Rhode Island AIDS Drug Assistance Program (ADAP) on the site, as well as a list of contact information for HIV/AIDS services and partners, including Ryan White HIV Care-funded programs. The programs listed range from clinics specializing in the medical care of HIV infected individuals to full service organizations that offer surveillance, anonymous testing, case management, clinical services, Sunrise House & Supportive Housing, prevention center (includes street outreach and needle exchange), and support groups. The AIDS Care Ocean State (http://www.aidscareos.org/Home.aspx) offers services such as patient advocacy, transportation, medical and mental health referrals, emergency assistance, respite care, rental assistance, housing subsidies, evictions prevention, and counseling (clinical, individual, group, and family).

Rhode Island is a small state where an estimated 85 percent of the HIV population receives care in the Immunology Clinic at the Brown-affiliated Miriam Hospital. We provide a description of the clinic's operations, to give an appreciation of how patients are handled in everyday life in a good program. People with new HIV diagnosis are referred to the clinic by work of mouth, referrals, and through the clinic's substantial outreach efforts.

#### Services Provided by the Immunology Clinic at the Miriam Hospital, RI

The clinic staff, comprising a multidisciplinary team of physicians (including mental health professionals), nurses, case managers, social workers, interpreters, and general support staff provides coordinated initial, follow-up, and triage care for immunologic and infectious disease patients. For all newly diagnosed or referred people, an experienced nurse conducts the initial assessment of preferred language, social, medical and mental health needs. Subsequently, a social worker or other experienced trained professional will act as the person's case manager, using a language interpreter, as needed. A nurse follows up after the initial assessment for further educational needs and to discuss medical questions. The case manager schedules the patient with a physician for an initial consult, triages the need for mental health or addiction support, and outlines an individualized multidisciplinary plan. The management plan is shared with the whole care team with the goal of providing a continuum of social and physical care.

People who present to the clinic have different needs, and thus the case manager must identify the most needed aspects of social and medical care. The case manager must act as the navigator of the patient through the existing system, because, existing resources within and outside the clinic are rarely integrated. For example, patient with housing needs may or may not be eligible for Part D Ryan White-funded programs, U.S. Housing and Urban Development programs (including Housing Opportunities for Persons With AIDS [HOPWA] programs), Salvation Army programs, or transitional assisted living programs that provide group or individual housing, depending on her income, insurance coverage, problems with the law, whether she is legally in the country, or whether she abuses drugs or alcohol. More generally, case workers work with other agencies in the state providing case management for HIV infected patients such as RI Project AIDS, AIDS Care Ocean State, and work with the state's Department of Health for contact tracing and finding loss to follow up patients.

Apart from housing, examples of social needs that the case manager caters to include but are not limited to food security; transportation; transitions from the hospital to a nursing unit, house, or other places providing hospitality; de novo or renewal applications to Ryan White Programs, AIDS Drug Assistance Programs, or public insurance such as Medicare or Medicaid (which is covering HIV patients since the institution of the Affordable Care Act); organization of day-to-day tasks; communication with jail or prison personnel, police, judges or others from the justice department. The case manager also acts as a financial advocate for patients in need. Through various funding sources, including Federal funding, hospital funds, in-kind-donations from pharmaceutical industry, and philanthropy, the clinic may cover application fees (e.g., for getting an identity card), burial expenses, drug co-pay, legal services, interpreter services, and many other unforeseen needs.

#### Alabama

A Google search for Alabama and HIV or AIDS yielded the Web site for the Division of HIV/AIDS Prevention and Care of Alabama Public Health (http://www.adph.org/aids/), which includes educational information, events, news, as well as links to services and care. There is an application for the Alabama AIDS Drug Assistance Program (ADAP) on the site, as well as a list of contact information for HIV/AIDS Program Coordinators in each of 11 areas of the state.

In the services section of the Web site is a list of links to 14 programs throughout the state. These range from clinics specializing in the medical care of HIV infected persons to full-service organizations that offer medical services (including obstetrics and gynecology services), housing, mental health, prevention/education, substance abuse treatment, and transportation. Most are based in a specific region of the state (north, south, central, Birmingham area, etc.), and receive Ryan White funds. Notably, the AIDS Alabama South (http://www.southalabamacares.org/) runs a monthly support group for HIV positive women. The AIDS Alabama (http://www.aidsalabama.org/) Web-based resource offers a zip-code-based locator for care in the state. The Birmingham AIDS Outreach (www.birminghamaidsoutreach.org) has a specific program focusing on Lesbian, Gay, Bisexual, Trans, and Queer (LGBTQ) people.

#### Mississippi

A Google search for Mississippi and HIV or AIDS yielded the Web site for the Mississippi State Department of Health (http://msdh.ms.gov/msdhsite/_static/14,0,150.html), which includes information on surveillance, epidemiology and research, education and policy, care and treatment, and public resources. There is an application for the Mississippi AIDS Drug Assistance Program on the site, as well as a list of contact persons for HIV/AIDS.

The programs listed on the site range from clinics specializing in the medical care of HIV infected persons to full service organizations that offer testing (conventional and/or rapid), counseling (includes support groups and one-on-one sessions), care and treatment (includes primary care, dental care, mental health care, etc.), legal services, and support services. Support services include drug purchases, transportation, childcare, emergency financial, housing (includes HOPWA), food, home care, respite care, and information dissemination (such as hotlines, electronic resources, print, etc.). Available programs and services can be searched by county and type of service. In addition there is a link for Your PSH (Personal Sexual Health), a free mobile app for Mississippi residents that gives users access to information and support for safe sexual health. The Mississippi GLBT Activism Society / Gay It Up! Mississippi links to specific programs for LGBTQ people. The Web site for Mississippi Center for Justice. This site includes information on employment, housing, and privacy rights for those living with HIV/AIDS.

#### New York

A Google search for New York and HIV or AIDS and programs yielded the New York State Living with HIV/AIDS site (https://www.health.ny.gov/diseases/aids/general/resources/), which contains a list of links broken down by topic: resource directories, family health care decision act, HIV uninsured care programs, child, family and others, Medicaid managed care, HIV special needs plans, and HIV and smoking. Under each topic it includes educational information, as well as introduction, policy, enrollment and contact information for HIV/AIDS services. There is an application for the New York AIDS Drug Assistance Program on the site.

These programs range from clinics specializing in the medical care for HIV infected individuals to full-service organizations that offer prevention education/risk reduction service, syringe exchange, opioid overdose prevention, STD screening, HIV testing, individual and group supportive counseling, case management, mental health, medical transportation, nutritional support, housing, and legal services. The services are also organized and provided by faith-based ministries, besides regular groups. LGBT Health and Human Services, and LGBT HIV/STD/hepatitis C Prevention Services, specifically addressing the needs of LGBTQ, are provided in all the regions of the state.

#### Texas

A Google search for Texas and HIV or AIDS yielded the Web site for the Texas Department of State Health Services (https://www.dshs.state.tx.us/hivstd/services/service_d.shtm). This site includes two main branches that deal with HIV/AIDS care: the Epidemiology and Surveillance Branch and the HIV/STD Prevention and Care Branch. The goals of these two branches are to provide HIV/STD education and information; collect, interpret, and distribute HIV data; give guidance and planning for HIV services; and provide medical supplies to prevent, manage, and treat HIV. This site also provides contact information for HIV programs organized by the program name, and information as to which programs accept patients regardless of immigration status.

The city of Austin has a Web site (https://austintexas.gov/department/austinhiv) that provides information for HIV education, testing, treatment, counseling, and a list of available HIV clinics and resources in Austin, specifically resources that provide assistance with medical care providers, medication, mental health, substance abuse services, case management, transportation, housing, food/nutrition, and employment. The Waterloo Counseling Center in Austin (http://www.waterloocounseling.org/index.html) offers transsexual/transgender specific support.

#### California

A Google search for California and (HIV or AIDS) yielded the Web sites of the California State Department of Public Health (https://www.cdph.ca.gov/) and of the California HIV/AIDS Service Referrals (https://npin.cdc.gov/ca/). The first site includes educational information, data and surveillance, resources, laws and regulations, as well as a list of links of HIV/AIDS services for various needs. The second site provides contact information of HIV/AIDS services in a selected region of the state (areas close to the address inputted). There is an application for the California AIDS Drug Assistance Program on both sites.

The services listed on the site range from clinics specializing in the medical care of HIV infected persons to full service organizations that provide prevention education, counseling, HIV testing (conventional and rapid), case management, support groups (HIV-positive or negative), faith-based HIV service, financial assistance, food, housing, legal services, medication adherence education and counseling, partner notification, and transportation. At the time of the search, these Web sites did not include any programs that focus on woman, senior citizens, or LGBTQ. Searching separately on Google for women, HIV, and specific cities or regions turns up several groups focused on women and/or the LGBT community. A group called HOPE publishes a California Healthcare Resource Guide for Undocumented Immigrants at http://www.hopeact.latinas.org/site/c.btJSL7NPJqL8H/b.8756551/k.DD38/ACA_and_the_Undocumented_Population_Resource_Guide.htm