# Appendix C Excluded Studies

PubMed ID | Title | Journal | Authors | Reason for exclusion
17136004 | An adherence typology: coping, quality of life, and physical symptoms of people living with HIV/AIDS and their adherence to antiretroviral treatment | Med Sci Monit | Bader, A.; Kremer, H.; Erlich-Trungenberger, I.; Rojas, R.; Lohmann, M.; Deobald, O.; Lochmann, R.; Altmeyer, P.; Brockmeyer, N. | Exclusively not in U.S.
16722349 | Bacterial pneumonia in the AIDS patients | West Afr J Med | Salami, A. K.; Olatunji, P. O.; Oluboyo, P. O.; Akanbi, A. A., 2nd; Fawibe, E. A. | Exclusively not in U.S.
24018492 | Non-invasive assessment of liver steatosis and fibrosis in HIV/HCV- and HCV- infected patients | Ann Hepatol | Li Vecchi, V.; Giannitrapani, L.; Di Carlo, P.; Mazzola, G.; Colletti, P.; La Spada, E.; Vizzini, G.; Montalto, G.; Soresi, M. | Exclusively not in U.S.
20163346 | Does HIV VCT reduce risk behaviors? An observational study in Guatemala City | Curr HIV Res | Samayoa, B.; Anderson, M. R.; O'Sullivan, L. F.; Patricia, K.; Pacheco, A.; Matos, A.; Reyes, D. A.; Setru, S.; Arathoon, E. | Exclusively not in U.S.
22010413 | Impact of oral health care needs on health-related quality of life in adult HIV+ patients | Acta Odontol Latinoam | Sanchez, G. A.; D'Eramo, L. R.; Lecumberri, R.; Squassi, A. F. | Exclusively not in U.S.
22716106 | Evaluation of mental status HIV-infected patients: implications for treatment | Curr HIV Res | Jin, Y. H.; Potthoff, A.; Xu, J.; Yu, W. J.; Liu, K.; Weng, N. C.; Brockmeyer, N. H.; Wu, N. P. | Exclusively not in U.S.
19936456 | Study of vascular reactivity in HIV patients whether or not receiving protease inhibitor | Arq Bras Cardiol | Teixeira, H. N.; Mesquita, E. T.; Ribeiro, M. L.; Bazin, A. R.; Mesquita, C. T.; Teixeira, M. P.; Pellegrini Rda, C.; Nobrega, A. C. | Exclusively not in U.S.
22332689 | Drug Interactions in Elderly Individuals with the Human Immunodeficiency Virus | Journal of the American Geriatrics Society | Darque, Albert | Exclusively not in U.S.
22390738 | Self-Regulatory Processes Mediate the Intention-Behavior Relation for Adherence and Exercise Behaviors | Health Psychology | de Bruin, Marijn; Kok, Gerjo; Prins, Jan M.; Sheeran, Paschal; Hiemstra, Anneke; Hospers, Harm J.; van Breukelen, Gerard J. P. | Exclusively not in U.S.
16326857 | Relation of sexual risks and prevention practices with individuals' stigmatising beliefs towards HIV infected individuals: an exploratory study | Sex Transm Infect | Liu, H.; Li, X.; Stanton, B.; Fang, X.; Mao, R.; Chen, X.; Yang, H. | Exclusively not in U.S.
20686104 | Families Suffering With HIV/AIDS: What Family Nursing Interventions Are Useful to Promote Healing? | Journal of Family Nursing | Chintana, Wacharasin | Exclusively not in U.S.
25747796 | Health service utilization of heroin abusers: a retrospective cohort study | Addict Behav | Chen, I. M. | Exclusively not in U.S.
23243129 | A model to predict the response to therapy against hepatitis C virus (HCV) including low-density lipoprotein receptor genotype in HIV/HCV-coinfected patients | J Antimicrob Chemother | Neukam, K.; Almeida, C.; Caruz, A.; Rivero-Juarez, A.; Rallon, N. I.; Di Lello, F. A.; Herrero, R.; Camacho, A.; Benito, J. M.; Macias, J.; Rivero, A.; Soriano, V.; Pineda, J. A. | Exclusively not in U.S.
21871086 | Admissions to intensive care unit of HIV-infected patients in the era of highly active antiretroviral therapy: etiology and prognostic factors | Crit Care | Chiang, H. H.; Hung, C. C.; Lee, C. M.; Chen, H. Y.; Chen, M. Y.; Sheng, W. H.; Hsieh, S. M.; Sun, H. Y.; Ho, C. C.; Yu, C. J. | Exclusively not in U.S.
22958583 | Associated factors for treatment delay in pulmonary tuberculosis in HIV-infected individuals: a nested case-control study | BMC Infect Dis | Coimbra, I.; Maruza, M.; Militao-Albuquerque Mde, F.; Moura, L. V.; Diniz, G. T.; Miranda-Filho Dde, B.; Lacerda, H. R.; Rodrigues, L. C.; Ximenes, R. A. | Exclusively not in U.S.
105069289. Language: | Electronic monitoring-based counseling to enhance adherence among HIV-infected patients: a randomized controlled trial | Health Psychology | de Bruin, M.; Hospers, H. J.; van Breukelen, G. J. P.; Kok, G.; Koevoets, W. M.; Prins, J. M. | Exclusively not in U.S.
21903660 | Liver toxicity associated with antiretroviral therapy including efavirenz or ritonavir-boosted protease inhibitors in a cohort of HIV/hepatitis C virus co-infected patients | J Antimicrob Chemother | Neukam, K.; Mira, J. A.; Ruiz-Morales, J.; Rivero, A.; Collado, A.; Torres-Cornejo, A.; Merino, D.; de Los Santos-Gil, I.; Macias, J.; Gonzalez-Serrano, M.; Camacho, A.; Parra-Garcia, G.; Pineda, J. A. | Exclusively not in U.S.
23417632 | Prevalence and clinical presentation of HIV positive female psychiatric inpatients | Afr J Psychiatry (Johannesbg) | Uys, H. | Exclusively not in U.S.
23980589 | Prognostic significance of the interval between the initiation of antiretroviral therapy and the initiation of anti-tuberculosis treatment in HIV/tuberculosis-coinfected patients: results from the TREAT Asia HIV Observational Database | HIV Med | Han, S. H.; Zhou, J.; Lee, M. P.; Zhao, H.; Chen, Y. M.; Kumarasamy, N.; Pujari, S.; Lee, C.; Omar, S. F.; Ditangco, R.; Phanuphak, N.; Kiertiburanakul, S.; Chaiwarith, R.; Merati, T. P.; Yunihastuti, E.; Tanuma, J.; Saphonn, V.; Sohn, A. H.; Choi, J. Y. | Exclusively not in U.S.
25659285 | Sofosbuvir plus ribavirin for treatment of hepatitis C virus in patients co-infected with HIV (PHOTON-2): a multicentre, open-label, non-randomised, phase 3 study | Lancet | Molina, J. M.; Orkin, C.; Iser, D. M.; Zamora, F. X.; Nelson, M.; Stephan, C.; Massetto, B.; Gaggar, A.; Ni, L.; Svarovskaia, E.; Brainard, D.; Subramanian, G. M.; McHutchison, J. G.; Puoti, M.; Rockstroh, J. K. | Exclusively not in U.S.
17002991 | The relationship between HIV/Sexually Transmitted Infection risk and alcohol use during commercial sex episodes: results from the study of female commercial sex workers in the Philippines | Subst Use Misuse | Chiao, C.; Morisky, D. E.; Rosenberg, R.; Ksobiech, K.; Malow, R. | Exclusively not in U.S.
18192292 | Unemployment as a risk factor for AIDS and death for HIV-infected patients in the era of highly active antiretroviral therapy | Sex Transm Infect | Delpierre, C.; Cuzin, L.; Lauwers-Cances, V.; Datta, G. D.; Berkman, L.; Lang, T. | Exclusively not in U.S.
18663046 | Contraception and medical gynaecology for HIV-positive women in a one-stop clinic | Int J STD AIDS | Samuel, M. I.; Welch, J.; Tenant-Flowers, M.; Brady, M.; Poulton, M.; Savvas, M.; Kumar, U.; Taylor, C. | Exclusively not in U.S.
25382350 | Improving hospital-based quality of care by reducing HIV-related stigma: evaluation results from Vietnam | AIDS Behav | Pulerwitz, J.; Oanh, K. T.; Akinwolemiwa, D.; Ashburn, K.; Nyblade, L. | Exclusively not in U.S.
18649341 | Isolated core antibody hepatitis B in sub-Saharan African immigrants | J Med Virol | Gibney, K. B.; Torresi, J.; Lemoh, C.; Biggs, B. A. | Exclusively not in U.S.
24553705 | Vulnerability of women living with HIV/AIDS | Rev Lat Am Enfermagem | Duarte, M. T.; Parada, C. M.; Souza Ldo, R. | Exclusively not in U.S.
106449101. Corporate | Influence of hepatitis C virus infection on HIV-1 disease progression and response to highly active antiretroviral therapy | Journal of Infectious Diseases | Rockstroh, J. K. | Exclusively not in U.S.
15872193 | A description of a peer-run supervised injection site for injection drug users | J Urban Health | Kerr, T.; Oleson, M.; Tyndall, M. W.; Montaner, J.; Wood, E. | Exclusively not in U.S.
19432546 | A double-blind, placebo-controlled trial of maraviroc in treatment-experienced patients infected with non-R5 HIV-1 | J Infect Dis | Saag, M.; Goodrich, J.; Fatkenheuer, G.; Clotet, B.; Clumeck, N.; Sullivan, J.; Westby, M.; van der Ryst, E.; Mayer, H. | Exclusively not in U.S.
2014-43793-008 | A grounded theory of social participation among older women living with HIV | Canadian Journal of Occupational Therapy / Revue Canadienne D'ErgothÃ©rapie | Siemon, Jennifer S.; Blenkhorn, Lisa; Wilkins, Seanne; Oâ€™Brien, Kelly K.; Solomon, Patricia E. | Exclusively not in U.S.
21431414 | A multilevel analysis of the impact of socio-structural and environmental influences on condom use among female sex workers | AIDS Behav | Ang, A.; Morisky, D. E. | Exclusively not in U.S.
20813564 | A new topical treatment protocol for oral hairy leukoplakia | Oral Surg Oral Med Oral Pathol Oral Radiol Endod | Moura, M. D.; Haddad, J. P.; Senna, M. I.; Ferreira e Ferreira, E.; Mesquita, R. A. | Exclusively not in U.S.
23115628 | A novel educational strategy targeting health care workers in underserved communities in Central America to integrate HIV into primary medical care | PLoS One | Flys, T.; Gonzalez, R.; Sued, O.; Suarez Conejero, J.; Kestler, E.; Sosa, N.; McKenzie-White, J.; Monzon,, II; Torres, C. R.; Page, K. | Exclusively not in U.S.
22341454 | A promising diagnostic tool for toxoplasmic encephalitis: tachyzoite/bradyzoite stage-specific RT-PCR | Int J Infect Dis | Sukthana, Y.; Mahittikorn, A.; Wickert, H.; Tansuphaswasdikul, S. | Exclusively not in U.S.
16216784 | A prospective, non-randomised phase 1-2 trial of VACOP-B with filgrastim support for HIV-related non-Hodgkin's lymphoma | Biotechnol Annu Rev | Sawka, C. A.; Shepherd, F. A.; Franssen, E.; Brandwein, J.; Dotten, D. A.; Routy, J. P.; Walker, I. R.; St-Louis, J.; Taylor, M.; Arts, K.; Crump, M.; Foote, M. | Exclusively not in U.S.
17961100 | Assessing self-reported adherence to HIV therapy by questionnaire: the SERAD (Self-Reported Adherence) Study | AIDS Res Hum Retroviruses | Munoz-Moreno, J. A.; Fumaz, C. R.; Ferrer, M. J.; Tuldra, A.; Rovira, T.; Viladrich, C.; Bayes, R.; Burger, D. M.; Negredo, E.; Clotet, B. | Exclusively not in U.S.
104835617. Corporate | Association of pharmacogenetic markers with premature discontinuation of first-line anti-HIV therapy: an observational cohort study | Journal of Infectious Diseases | Lubomirov, R.; Colombo, S.; di Iulio, J.; Ledergerber, B.; Martinez, R.; Cavassini, M.; Hirschel, B.; Bernasconi, E.; Elzi, L.; Vernazza, P.; Furrer, H.; GÃ¼nthard, H. F.; Telenti, A. | Exclusively not in U.S.
24176943 | Changes to antiretroviral drug regimens during integrated TB-HIV treatment: results of the SAPiT trial | Antivir Ther | Naidoo, A.; Naidoo, K.; Yende-Zuma, N.; Gengiah, T. N.; Padayatchi, N.; Gray, A. L.; Bamber, S.; Nair, G.; Karim, S. S. | Exclusively not in U.S.
104376858. Corporate | Comparison of high ribavirin induction versus standard ribavirin dosing, plus peginterferon-[alpha] for the treatment of chronic hepatitis C in HIV-infected patients: the PERICO trial | Journal of Infectious Diseases | Labarga, P.; Barreiro, P.; da Silva, A.; Guardiola, J. M.; Rubio, R.; Aguirrebengoa, K.; Miralles, P.; Portu, J.; TÃ©llez, M. J.; Morano, L.; Castro, A.; Pineda, J. A.; TerrÃ³n, A.; HernÃ¡ndez-Quero, J.; MariÃ±o, A.; RÃos, M. J.; EcheverrÃa, S.; Asensi, V.; Vispo, E.; Soriano, V. | Exclusively not in U.S.
19662759 | Dyslipidemia and adherence to the Mediterranean diet in Croatian HIV-infected patients during the first year of highly active antiretroviral therapy | Coll Antropol | Turcinov, D.; Stanley, C.; Canchola, J. A.; Rutherford, G. W.; Novotny, T. E.; Begovac, J. | Exclusively not in U.S.
20428637 | Effectiveness of highly active antiretroviral therapy (HAART) used concomitantly with rifampicin in patients with tuberculosis and AIDS | Braz J Infect Dis | Sant'Anna, F. M.; Velasque, L.; Costa, M. J.; Schmaltz, C. A.; Morgado, M. G.; Lourenco, M. C.; Grinsztejn, B.; Rolla, V. C. | Exclusively not in U.S.
22532465 | Efficacy and safety of rilpivirine in treatment-naive, HIV-1-infected patients with hepatitis B virus/hepatitis C virus coinfection enrolled in the Phase III randomized, double-blind ECHO and THRIVE trials | J Antimicrob Chemother | Nelson, M.; Amaya, G.; Clumeck, N.; Arns da Cunha, C.; Jayaweera, D.; Junod, P.; Li, T.; Tebas, P.; Stevens, M.; Buelens, A.; Vanveggel, S.; Boven, K. | Exclusively not in U.S.
17625761 | Efficacy of amphotericin B in a fat emulsion for the treatment of cryptococcal meningitis in AIDS patients | Braz J Infect Dis | Rubio, F. G.; Zanon, J. R.; de Almeida, M. T.; de Gongora, D. V. | Exclusively not in U.S.
24660762 | Evaluation of human immunodeficiency virus infection-related left ventricular systolic dysfunction by tissue Doppler strain echocardiography | Echocardiography | Onur, I.; Ikitimur, B.; Oz, F.; Ekmekci, A.; Elitok, A.; Cagatay, A. A.; Adalet, K.; Bilge, A. K.; Kaya, M. G. | Exclusively not in U.S.
23607445 | HCV clearance from saliva of HIV-HCV-coinfected patients on treatment with interferon plus ribavirin | Oral Dis | Feijoo, J.; Eirea, M.; Limeres, J.; Abeleira, M.; Ramos, I.; Ocampo, A.; Diz, P. | Exclusively not in U.S.
25234379 | Hospital and ambulatory management, and compliance to treatment in HIV infection: regional health insurance agency analysis | Med Mal Infect | Hassen-Khodja, C.; Gras, G.; Grammatico-Guillon, L.; Dupuy, C.; Gomez, J. F.; Freslon, L.; Dailloux, J. F.; Soufflet, A.; Bernard, L. | Exclusively not in U.S.
19466962 | Imiquimod 5% cream for external genital or perianal warts in human immunodeficiency virus-positive patients treated with highly active antiretroviral therapy: an open-label, noncomparative study | Br J Dermatol | Saiag, P.; Bauhofer, A.; Bouscarat, F.; Aquilina, C.; Ortonne, J. P.; Dupin, N.; Mougin, C. | Exclusively not in U.S.
26196665 | Ledipasvir and Sofosbuvir for HCV in Patients Coinfected with HIV-1 | N Engl J Med | Naggie, S.; Cooper, C.; Saag, M.; Workowski, K.; Ruane, P.; Towner, W. J.; Marks, K.; Luetkemeyer, A.; Baden, R. P.; Sax, P. E.; Gane, E.; Santana-Bagur, J.; Stamm, L. M.; Yang, J. C.; German, P.; Dvory-Sobol, H.; Ni, L.; Pang, P. S.; McHutchison, J. G.; Stedman, C. A.; Morales-Ramirez, J. O.; Brau, N.; Jayaweera, D.; Colson, A. E.; Tebas, P.; Wong, D. K.; Dieterich, D.; Sulkowski, M. | Exclusively not in U.S.
16269184 | Pegylated interferon alpha-2b plus ribavirin for the treatment of chronic hepatitis C in HIV-coinfected patients | J Infect | Voigt, E.; Schulz, C.; Klausen, G.; Goelz, J.; Mauss, S.; Schmutz, G.; Jessen, H.; Weitner, L.; Mutz, A.; Schranz, D.; Rockstroh, J. K. | Exclusively not in U.S.
23260763 | Pneumocystis jirovecii genotype associated with increased death rate of HIV-infected patients with pneumonia | Emerg Infect Dis | Rabodonirina, M.; Vaillant, L.; Taffe, P.; Nahimana, A.; Gillibert, R. P.; Vanhems, P.; Hauser, P. M. | Exclusively not in U.S.
24244647 | Predictive factors of herpes zoster HIV-infected patients: another adverse effect of crack cocaine | PLoS One | Nacher, M.; Basurko, C.; Adenis, A.; Gaubert-Marechal, E.; Mosnier, E.; Edouard, S.; Vantilcke, V.; Sivapregassam, S.; Tressieres, B.; Cabie, A.; Couppie, P. | Exclusively not in U.S.
18925321 | Progressive resistance training in elderly HIV-positive patients: does it work? | Clinics (Sao Paulo) | Souza, P. M.; Jacob-Filho, W.; Santarem, J. M.; Silva, A. R.; Li, H. Y.; Burattini, M. N. | Exclusively not in U.S.
105438694. Language: | Radiation therapy for HIV-associated diffuse large cell non-Hodgkin lymphoma | JIAPAC: Journal of the International Association of Physicians in AIDS Care | Rothschild, S.; Dolder, M.; Seifert, B.; LÃ¼tolf, U. M.; Ciernik, I. F. | Exclusively not in U.S.
19955873 | Reducing sexual risk behavior among steady heterosexual serodiscordant couples in a testing and counseling program | Sex Transm Dis | Hernando, V.; del Romero, J.; Garcia, S.; Rodriguez, C.; del Amo, J.; Castilla, J. | Exclusively not in U.S.
22007690 | Safety and tolerability of varenicline tartrate (Champix((R))/Chantix((R))) for smoking cessation in HIV-infected subjects: a pilot open-label study | AIDS Patient Care STDS | Cui, Q.; Robinson, L.; Elston, D.; Smaill, F.; Cohen, J.; Quan, C.; McFarland, N.; Thabane, L.; McIvor, A.; Zeidler, J.; Smieja, M. | Exclusively not in U.S.
21850442 | Sticking to it: the effect of maximally assisted therapy on antiretroviral treatment adherence among individuals living with HIV who are unstably housed | AIDS Behav | Parashar, S.; Palmer, A. K.; O'Brien, N.; Chan, K.; Shen, A.; Coulter, S.; Montaner, J. S.; Hogg, R. S. | Exclusively not in U.S.
15829028 | Study of patients diagnosed with advanced HIV in the HAART era--OMEGA Cohort | Int J STD AIDS | Santos, J.; Palacios, R.; Ruiz, J.; Gonzalez, M.; Marquez, M. | Exclusively not in U.S.
17411390 | Substance use and sexual behaviors among Japanese tourists, students, and temporary workers in Honolulu, Hawaii | AIDS Educ Prev | Nemoto, T.; Iwamoto, M.; Morris, A.; Yokota, F.; Wada, K. | Exclusively not in U.S.
25300708 | Successful MDR-TB treatment regimens including amikacin are associated with high rates of hearing loss | BMC Infect Dis | Modongo, C.; Sobota, R. S.; Kesenogile, B.; Ncube, R.; Sirugo, G.; Williams, S. M.; Zetola, N. M. | Exclusively not in U.S.
19922624 | Survey of both hepatitis B virus (HBsAg) and hepatitis C virus (HCV-Ab) coinfection among HIV positive patients | Virol J | Mohammadi, M.; Talei, G.; Sheikhian, A.; Ebrahimzade, F.; Pournia, Y.; Ghasemi, E.; Boroun, H. | Exclusively not in U.S.
22410415 | Survival of HIV-infected patients after starting tuberculosis treatment: a prospective cohort study | Int J Tuberc Lung Dis | Maruza, M.; Albuquerque, M. F.; Braga, M. C.; Barbosa, M. T.; Byington, R.; Coimbra, I.; Moura, L. V.; Batista, J. D.; Diniz, G. T.; Miranda-Filho, D. B.; Lacerda, H. R.; Rodrigues, L. C.; Ximenes, R. A. | Exclusively not in U.S.
106532327. Language: | The evaluation of a Latino community health worker HIV prevention program | Hispanic Journal of Behavioral Sciences | Martin, M.; Camargo, M.; Ramos, L.; Lauderdale, D.; Krueger, K.; Lantos, J. | Exclusively not in U.S.
19266411 | The influence of the patients' educational levels on socioeconomic, clinical, immunological and virological endpoints | AIDS Care | Collazos, J.; Asensi, V.; Carton, J. A.; Ibarra, S. | Exclusively not in U.S.
23473586 | Where sex ends and emotions begin': love and HIV risk among female sex workers and their intimate, noncommercial partners along the Mexico-US border | Cult Health Sex | Syvertsen, J. L.; Robertson, A. M.; Palinkas, L. A.; Rangel, M. G.; Martinez, G.; Strathdee, S. A. | Exclusively not in U.S.
18834909 | A rapid immunochromatographic assay for the detection of Mycobacterium tuberculosis antigens in pulmonary samples from HIV seropositive patients and its comparison with conventional methods | J Microbiol Methods | Chakraborty, N.; Bhattacharyya, S.; De, C.; Mukherjee, A.; Sarkar, R. N.; Banerjee, D.; Chakraborti, S.; Bhattacharyya, S. K. | Exclusively not in U.S.
24551079 | Abriendo Puertas: baseline findings from an integrated intervention to promote prevention, treatment and care among FSW living with HIV in the Dominican Republic | PLoS One | Donastorg, Y.; Barrington, C.; Perez, M.; Kerrigan, D. | Exclusively not in U.S.
21267059 | Development of a standardized screening rule for tuberculosis in people living with HIV in resource-constrained settings: individual participant data meta-analysis of observational studies | PLoS Med | Getahun, H.; Kittikraisak, W.; Heilig, C. M.; Corbett, E. L.; Ayles, H.; Cain, K. P.; Grant, A. D.; Churchyard, G. J.; Kimerling, M.; Shah, S.; Lawn, S. D.; Wood, R.; Maartens, G.; Granich, R.; Date, A. A.; Varma, J. K. | Exclusively not in U.S.
103759178. Language: | Effect of Aging, Glucose Level, and HIV Viral Load on Response to Treatment with Pegylated Interferon Plus Ribavirin in HIV/HCV Co-Infected Women | Journal of Women's Health (15409996) | Nasta, Paola; Maida, Ivana; Cattelan, Anna Maria; Pontali, Emanuele; Angeli, Elena; Giralda, Mariarosaria; Verucchi, Gabriella; Caputo, Antonietta; Iannacone, Claudio; Puoti, Massimo; Carosi, Giampiero | Exclusively not in U.S.
24888938 | Evaluation of a single-visit approach to cervical cancer screening and treatment in Guyana: feasibility, effectiveness and lessons learned | J Obstet Gynaecol Res | Martin, C. E.; Tergas, A. I.; Wysong, M.; Reinsel, M.; Estep, D.; Varallo, J. | Exclusively not in U.S.
23973400 | Evaluation of a strategy aimed at reducing errors in antiretroviral prescriptions for hospitalized HIV-infected patients | Med Mal Infect | Lauzevis, S.; Chaix, F.; Lazzerini, C. | Exclusively not in U.S.
19670415 | Fast fibrosis progression between repeated liver biopsies in patients coinfected with human immunodeficiency virus/hepatitis C virus | Hepatology | Macias, J.; Berenguer, J.; Japon, M. A.; Giron, J. A.; Rivero, A.; Lopez-Cortes, L. F.; Moreno, A.; Gonzalez-Serrano, M.; Iribarren, J. A.; Ortega, E.; Miralles, P.; Mira, J. A.; Pineda, J. A. | Exclusively not in U.S.
22905704 | Implementation and effect of intensified case finding on diagnosis of tuberculosis in a large urban HIV clinic in Uganda: a retrospective cohort study | BMC Public Health | Hermans, S.; Nasuuna, E.; van Leth, F.; Byhoff, E.; Schwarz, M.; Hoepelman, A.; Lange, J.; Manabe, Y. C. | Exclusively not in U.S.
25105798 | Increased costs of HIV care associated with aging in an HIV-infected population | HIV Med | Krentz, H. B.; Gill, M. J. | Exclusively not in U.S.
25365974 | Long-term protection from isoniazid preventive therapy for tuberculosis in HIV-infected patients in a medium-burden tuberculosis setting: the TB/HIV in Rio (THRio) study | Clin Infect Dis | Golub, J. E.; Cohn, S.; Saraceni, V.; Cavalcante, S. C.; Pacheco, A. G.; Moulton, L. H.; Durovni, B.; Chaisson, R. E. | Exclusively not in U.S.
109814389. Language: | Patient Perspectives on Leaving, Disengaging, and Returning to HIV Care | AIDS Patient Care & STDs | Gill, Victoria C.; Krentz, Hartmut B. | Exclusively not in U.S.
23197168 | Potent antiretroviral therapy for human immunodeficiency virus infection increases aortic stiffness | Arq Bras Cardiol | Eira, M.; Bensenor, I. M.; Dorea, E. L.; Cunha, R. S.; Mill, J. G.; Lotufo, P. A. | Exclusively not in U.S.
18425282 | Recurrence of cervical intraepithelial neoplasia grades 2 or 3 in HIV-infected women treated by large loop excision of the transformation zone (LLETZ) | Sao Paulo Med J | Russomano, F.; Reis, A.; Camargo, M. J.; Grinsztejn, B.; Tristao, M. A. | Exclusively not in U.S.
24269677 | Sustained virological response in HIV/HCV co-infected patients treated with pegylated interferon/ribavirin can be predicted from the overall rate of viral load decline over the first 4 weeks of therapy | J Infect | Rivero-Juarez, A.; Neukam, K.; Labarga, P.; Camacho, A.; Macias, J.; Barreiro, P.; Torre-Cisneros, J.; Pineda, J. A.; Soriano, V.; Rivero, A. | Exclusively not in U.S.
24474009 | The effects of a diet formulation with oats, soybeans, and flax on lipid profiles and uricemia in patients with AIDS and dyslipidemia | Rev Soc Bras Med Trop | Ferreira Rdos, S.; Cassaro, D. C.; Domingos, H.; Pontes, E. R.; Aiko, P. H.; Meira, J. E. | Exclusively not in U.S.
19033475 | The efficacy of a US-based medicine recycling program delivering antiretroviral drugs worldwide | J Int Assoc Physicians AIDS Care (Chic) | Patrick, P. A.; Jibilian, A.; Herasme, O.; Valencia, J.; Hernandez, E. C.; Jurado, S.; Aguais, J. | Exclusively not in U.S.
23065463 | Baseline risk factors for relapse in HIV/HCV co-infected patients treated with PEG-IFN/RBV | Infection | Rivero-Juarez, A.; Mira, J. A.; Camacho, A.; Neukam, K.; Perez-Camacho, I.; Caruz, A.; Macias, J.; Torre-Cisneros, J.; Pineda, J. A.; Rivero, A. | Exclusively not in U.S.
20493576 | Comparison of liver fibrosis blood tests developed for HCV with new specific tests in HIV/HCV co-infection | J Hepatol | Cales, P.; Halfon, P.; Batisse, D.; Carrat, F.; Perre, P.; Penaranda, G.; Guyader, D.; d'Alteroche, L.; Fouchard-Hubert, I.; Michelet, C.; Veillon, P.; Lambert, J.; Weiss, L.; Salmon, D.; Cacoub, P. | Exclusively not in U.S.
21274869 | Liver transplantation for hepatocellular carcinoma: the impact of human immunodeficiency virus infection | Hepatology | Vibert, E.; Duclos-Vallee, J. C.; Ghigna, M. R.; Hoti, E.; Salloum, C.; Guettier, C.; Castaing, D.; Samuel, D.; Adam, R. | N<10
23532683 | Tolerance and toxicity of primary radiation therapy in the management of seropositive HIV patients with squamous cell carcinoma of the head and neck | Laryngoscope | Mourad, W. F.; Hu, K. S.; Ishihara, D.; Shourbaji, R. A.; Lin, W.; Kumar, M.; Jacobson, A. S.; Tran, T.; Manolidis, S.; Urken, M.; Persky, M.; Harrison, L. | N<10
18793085 | 18F-fluorodeoxyglucose positron emission tomography/computed tomography in AIDS-related Burkitt lymphoma | AIDS Patient Care STDS | Just, P. A.; Fieschi, C.; Baillet, G.; Galicier, L.; Oksenhendler, E.; Moretti, J. L. | N<10
19625372 | A pilot randomized trial comparing an intensive versus a standard intervention in stable HIV-infected patients with moderate-high cardiovascular risk | J Antimicrob Chemother | Masia, M.; Bernal, E.; Padilla, S.; Garcia, N.; Escribano, J. C.; Martinez, E.; Gutierrez, F. | N<10
22458375 | A pilot study of the effects of internet-based cognitive stimulation on neuropsychological function in HIV disease | Disabil Rehabil | Becker, J. T.; Dew, M. A.; Aizenstein, H. J.; Lopez, O. L.; Morrow, L.; Saxton, J.; Tarraga, L. | N<10
18627279 | A qualitative examination of the indirect effects of modified directly observed therapy on health behaviors other than adherence | AIDS Patient Care STDS | Bradley-Ewing, A.; Thomson, D.; Pinkston, M.; Goggin, K. J. | N<10
16338772 | A qualitative study of persons who are 100% adherent to antiretroviral therapy | AIDS Care | Lewis, M. P.; Colbert, A.; Erlen, J.; Meyers, M. | N<10
17109305 | A trial of integrated buprenorphine/naloxone and HIV clinical care | Clin Infect Dis | Sullivan, L. E.; Barry, D.; Moore, B. A.; Chawarski, M. C.; Tetrault, J. M.; Pantalon, M. V.; O'Connor, P. G.; Schottenfeld, R. S.; Fiellin, D. A. | N<10
15883411 | AIDS-related Burkitt's lymphoma versus diffuse large-cell lymphoma in the pre-highly active antiretroviral therapy (HAART) and HAART eras: significant differences in survival with standard chemotherapy | J Clin Oncol | Lim, S. T.; Karim, R.; Nathwani, B. N.; Tulpule, A.; Espina, B.; Levine, A. M. | N<10
25942456 | Altered Monoamine and Acylcarnitine Metabolites in HIV-Positive and HIV-Negative Subjects With Depression | J Acquir Immune Defic Syndr | Cassol, E.; Misra, V.; Morgello, S.; Kirk, G. D.; Mehta, S. H.; Gabuzda, D. | N<10
17959343 | An open-label pilot study of high-concentration capsaicin patch in painful HIV neuropathy | J Pain Symptom Manage | Simpson, D. M.; Estanislao, L.; Brown, S. J.; Sampson, J. | N<10
23082133 | Angiotensin converting enzyme inhibitor and HMG-CoA reductase inhibitor as adjunct treatment for persons with HIV infection: a feasibility randomized trial | PLoS One | Baker, J. V.; Huppler Hullsiek, K.; Prosser, R.; Duprez, D.; Grimm, R.; Tracy, R. P.; Rhame, F.; Henry, K.; Neaton, J. D. | N<10
17505167 | Biochemical and virologic parameters in patients co-infected with hepatitis C and HIV versus patients with hepatitis C mono-infection | Am J Med Sci | Butt, A. A.; Tsevat, J.; Ahmad, J.; Shakil, A. O.; Mrus, J. M. | N<10
25007250 | CD127 expression, exhaustion status and antigen specific proliferation predict sustained virologic response to IFN in HCV/HIV co-infected individuals | PLoS One | Kared, H.; Saeed, S.; Klein, M. B.; Shoukry, N. H. | N<10
24449348 | CD4/CD8 ratio is a promising candidate for non-invasive measurement of liver fibrosis in chronic HCV-monoinfected patients | Eur J Clin Microbiol Infect Dis | Feuth, T.; van Baarle, D.; van Erpecum, K. J.; Siersema, P. D.; Hoepelman, A. I.; Arends, J. E. | N<10
22011066 | Clinical presentation, treatment, and outcomes among 65 patients with HIV-associated lymphoma treated at the University of North Carolina, 2000-2010 | AIDS Res Hum Retroviruses | Gopal, S.; Martin, K. E.; Richards, K. L.; Eron, J. J. | N<10
22536930 | Correlates of antiretroviral and antidepressant adherence among depressed HIV-infected patients | AIDS Patient Care STDS | Bottonari, K. A.; Tripathi, S. P.; Fortney, J. C.; Curran, G.; Rimland, D.; Rodriguez-Barradas, M.; Gifford, A. L.; Pyne, J. M. | N<10
16003227 | Cyclosporine pharmacokinetics and dosing modifications in human immunodeficiency virus-infected liver and kidney transplant recipients | Transplantation | Frassetto, L.; Baluom, M.; Jacobsen, W.; Christians, U.; Roland, M. E.; Stock, P. G.; Carlson, L.; Benet, L. Z. | N<10
23406479 | Damaging what wasn't damaged already': psychological tension and antiretroviral adherence among HIV-infected methadone-maintained drug users | AIDS Care | Batchelder, A. W.; Brisbane, M.; Litwin, A. H.; Nahvi, S.; Berg, K. M.; Arnsten, J. H. | N<10
23332014 | Developing a personal health record self-efficacy tool | Appl Nurs Res | Nokes, K. M.; Verkuilen, J.; Hickey, D. E.; James-Borga, J. C.; Shan, J. | N<10
23407015 | Development and evaluation of an internet and personal health record training program for low-income patients with HIV or hepatitis C | Med Care | McInnes, D. K.; Solomon, J. L.; Shimada, S. L.; Petrakis, B. A.; Bokhour, B. G.; Asch, S. M.; Nazi, K. M.; Houston, T. K.; Gifford, A. L. | N<10
24029625 | Development of a personalized bidirectional text messaging tool for HIV adherence assessment and intervention among substance abusers | J Subst Abuse Treat | Ingersoll, K.; Dillingham, R.; Reynolds, G.; Hettema, J.; Freeman, J.; Hosseinbor, S.; Winstead-Derlega, C. | N<10
21154261 | Doppler tissue imaging unmasks right ventricular function abnormalities in HIV-infected patients | Cardiol J | Karavidas, A.; Tsiachris, D.; Lazaros, G.; Xylomenos, G.; Arapi, S.; Potamitis, N.; Matzaraki, V.; Caplanis, J.; Matsakas, E.; Gargalianos, P.; Pyrgakis, V.; Stefanadis, C. | N<10
21371580 | Durability of antibody responses after receipt of the monovalent 2009 pandemic influenza A (H1N1) vaccine among HIV-infected and HIV-uninfected adults | Vaccine | Crum-Cianflone, N. F.; Iverson, E.; Defang, G.; Blair, P. J.; Eberly, L. E.; Maguire, J.; Ganesan, A.; Faix, D.; Duplessis, C.; Lalani, T.; Whitman, T.; Brandt, C.; Macalino, G.; Millar, E. V.; Burgess, T. | N<10
21220657 | Effectiveness of collaborative care for depression in human immunodeficiency virus clinics | Arch Intern Med | Pyne, J. M.; Fortney, J. C.; Curran, G. M.; Tripathi, S.; Atkinson, J. H.; Kilbourne, A. M.; Hagedorn, H. J.; Rimland, D.; Rodriguez-Barradas, M. C.; Monson, T.; Bottonari, K. A.; Asch, S. M.; Gifford, A. L. | N<10
23394825 | Effects of behavioral stress reduction Transcendental Meditation intervention in persons with HIV | AIDS Care | Chhatre, S.; Metzger, D. S.; Frank, I.; Boyer, J.; Thompson, E.; Nidich, S.; Montaner, L. J.; Jayadevappa, R. | N<10
17064957 | Efficacy and safety of peg-IFN alfa-2a with ribavirin for the treatment of HCV/HIV coinfected patients who failed previous IFN based therapy | J Clin Virol | Rodriguez-Torres, M.; Rodriguez-Orengo, J. F.; Rios-Bedoya, C. F.; Fernandez-Carbia, A.; Gonzalez-Lassalle, E.; Salgado-Mercado, R.; Marxuach-Cuetara, A. M. | N<10
20920996 | Efficacy and toxicity of chemoradiation in the treatment of HIV-associated anal cancer | Clin Colorectal Cancer | Hauerstock, D.; Ennis, R. D.; Grossbard, M.; Evans, A. | N<10
18567911 | Efficacy of pegylated interferon and ribavirin for retreatment of chronic HCV infection in HIV co-infected patients failing a previous standard interferon-based regimen | J Antimicrob Chemother | Crespo, M.; Mira, J. A.; Pineda, J. A.; Van den Eynde, E.; Rios-Villegas, M. J.; Collado, A.; Giron-Gonzalez, J. A.; Lopez-Cortes, L. F.; Gonzalez-Serrano, M.; Rivero, A.; Merino, D.; Esteban, J. I. | N<10
24326607 | Epidemiology of head and neck squamous cell cancer among HIV-infected patients | J Acquir Immune Defic Syndr | D'Souza, G.; Carey, T. E.; William, W. N., Jr.; Nguyen, M. L.; Ko, E. C.; Riddell, J. th; Pai, S. I.; Gupta, V.; Walline, H. M.; Lee, J. J.; Wolf, G. T.; Shin, D. M.; Grandis, J. R.; Ferris, R. L. | N<10
19260770 | Experiences of stigma and discrimination among adults living with HIV in a low HIV-prevalence context: a qualitative analysis | AIDS Patient Care STDS | Zukoski, A. P.; Thorburn, S. | N<10
22959481 | Exploratory study: evaluating the effects of fish oil and controlled diet to reduce triglyceride levels in HIV | J Assoc Nurses AIDS Care | Capili, B.; Anastasi, J. K. | N<10
17971707 | Fish oil and fenofibrate for the treatment of hypertriglyceridemia in HIV-infected subjects on antiretroviral therapy: results of ACTG A5186 | J Acquir Immune Defic Syndr | Gerber, J. G.; Kitch, D. W.; Fichtenbaum, C. J.; Zackin, R. A.; Charles, S.; Hogg, E.; Acosta, E. P.; Connick, E.; Wohl, D.; Kojic, E. M.; Benson, C. A.; Aberg, J. A. | N<10
17058240 | HCV kinetics, quasispecies, and clearance in treated HCV-infected and HCV/HIV-1-coinfected patients with hemophilia | Hepatology | Shire, N. J.; Horn, P. S.; Rouster, S. D.; Stanford, S.; Eyster, M. E.; Sherman, K. E. | N<10
19645620 | Health-related beliefs and decisions about accessing HIV medical care among HIV-infected persons who are not receiving care | AIDS Patient Care STDS | Beer, L.; Fagan, J. L.; Valverde, E.; Bertolli, J. | N<10
24592920 | Healthcare provider perspectives on barriers to HIV-care access and utilisation among Latinos living with HIV in the US-Mexico border | Cult Health Sex | Servin, A. E.; Munoz, F. A.; Zuniga, M. L. | N<10
24277743 | Hepatitis C therapy with interferon-alpha and ribavirin reduces CD4 T-cell-associated HIV-1 DNA in HIV-1/hepatitis C virus-coinfected patients | J Infect Dis | Sun, H.; Buzon, M. J.; Shaw, A.; Berg, R. K.; Yu, X. G.; Ferrando-Martinez, S.; Leal, M.; Ruiz-Mateos, E.; Lichterfeld, M. | N<10
15744337 | High incidence of Kaposi sarcoma-associated herpesvirus infection in HIV-related solid immunoblastic/plasmablastic diffuse large B-cell lymphoma | Leukemia | Deloose, S. T.; Smit, L. A.; Pals, F. T.; Kersten, M. J.; van Noesel, C. J.; Pals, S. T. | N<10
22269705 | Human immunodeficiency virus infection as a prognostic factor in surgical patients with non-small cell lung cancer | Ann Thorac Surg | Hooker, C. M.; Meguid, R. A.; Hulbert, A.; Taylor, J. T.; Shin, J.; Wrangle, J.; Rodgers, K.; Lee, B.; Laskshmanan, S.; Brown, T.; Meneshian, A.; Sussman, M.; Keruly, J.; Moore, R. D.; Yang, S. C.; Brock, M. V. | N<10
18202423 | Human immunodeficiency virus-associated squamous cell cancer of the anus: epidemiology and outcomes in the highly active antiretroviral therapy era | J Clin Oncol | Chiao, E. Y.; Giordano, T. P.; Richardson, P.; El-Serag, H. B. | N<10
25114140 | Impact of lopinavir-ritonavir or nevirapine on bedaquiline exposures and potential implications for patients with tuberculosis-HIV coinfection | Antimicrob Agents Chemother | Svensson, E. M.; Dooley, K. E.; Karlsson, M. O. | N<10
20177974 | Improved HIV and substance abuse treatment outcomes for released HIV-infected prisoners: the impact of buprenorphine treatment | J Urban Health | Springer, S. A.; Chen, S.; Altice, F. L. | N<10
22235243 | Influence of IL28B polymorphisms on response to a lower-than-standard dose peg-IFN-alpha 2a for genotype 3 chronic hepatitis C in HIV-coinfected patients | PLoS One | Lopez-Cortes, L. F.; Ruiz-Valderas, R.; Jimenez-Jimenez, L.; Gonzalez-Escribano, M. F.; Torres-Cornejo, A.; Mata, R.; Rivero, A.; Pineda, J. A.; Marquez-Solero, M.; Viciana, P. | N<10
15665633 | Integration of motivational interviewing and cognitive behavioral therapy to improve HIV medication adherence and reduce substance use among HIV-positive men and women: results of a pilot project | AIDS Patient Care STDS | Parsons, J. T.; Rosof, E.; Punzalan, J. C.; Di Maria, L. | N<10
23713756 | Internet-based video-group delivery of Healthy Relationships--a ‘prevention with positives’ intervention: report on a single group pilot test among women living with HIV | AIDS Care | Marhefka, S. L.; Iziduh, S.; Fuhrmann, H. J.; Lopez, B.; Glueckauf, R.; Lynn, V.; Baldwin, J. | N<10
19952286 | Lack of fluoroquinolone resistance in non-typhoidal salmonella bacteremia in HIV-infected patients in an urban US setting | J Int Assoc Physicians AIDS Care (Chic) | Forrest, G. N.; Wagner, L. A.; Talwani, R.; Gilliam, B. L. | N<10
21046470 | Linking HIV-positive jail inmates to treatment, care, and social services after release: results from a qualitative assessment of the COMPASS Program | J Urban Health | Nunn, A.; Cornwall, A.; Fu, J.; Bazerman, L.; Loewenthal, H.; Beckwith, C. | N<10
17105512 | Lipid abnormalities in HIV/hepatitis C virus-coinfected patients | HIV Med | Bedimo, R.; Ghurani, R.; Nsuami, M.; Turner, D.; Kvanli, M. B.; Brown, G.; Margolis, D. | N<10
25038306 | Long-term effects of an intensive intervention in HIV-infected patients with moderate-high atherosclerotic cardiovascular risk | J Antimicrob Chemother | Masia, M.; Bernal, E.; Robledano, C.; Padilla, S.; Lopez, N.; Martinez, E.; Gutierrez, F. | N<10
20538187 | Long-term safety of NGX-4010, a high-concentration capsaicin patch, in patients with peripheral neuropathic pain | J Pain Symptom Manage | Simpson, D. M.; Gazda, S.; Brown, S.; Webster, L. R.; Lu, S. P.; Tobias, J. K.; Vanhove, G. F. | N<10
21424854 | Longitudinal evaluation of occult hepatitis B infection in HIV-1 infected individuals during highly active antiretroviral treatment interruption and after HAART resumption | Infection | Bagaglio, S.; Bianchi, G.; Danise, A.; Porrino, L.; Uberti-Foppa, C.; Lazzarin, A.; Castagna, A.; Morsica, G. | N<10
18678242 | Mindfulness meditation training effects on CD4+ T lymphocytes in HIV-1 infected adults: a small randomized controlled trial | Brain Behav Immun | Creswell, J. D.; Myers, H. F.; Cole, S. W.; Irwin, M. R. | N<10
23475640 | Mixed-methods evaluation of a telehealth collaborative care program for persons with HIV infection in a rural setting | J Gen Intern Med | Ohl, M.; Dillon, D.; Moeckli, J.; Ono, S.; Waterbury, N.; Sissel, J.; Yin, J.; Neil, B.; Wakefield, B.; Kaboli, P. | N<10
20036267 | Neurocognitive correlates of alexithymia in asymptomatic individuals with HIV | Neuropsychologia | Bogdanova, Y.; Diaz-Santos, M.; Cronin-Golomb, A. | N<10
23098696 | Open-label, randomized, parallel-group controlled clinical trial of massage for treatment of depression in HIV-infected subjects | J Altern Complement Med | Poland, R. E.; Gertsik, L.; Favreau, J. T.; Smith, S. I.; Mirocha, J. M.; Rao, U.; Daar, E. S. | N<10
18815979 | Participants' perspectives on cognitive-behavioral therapy for adherence and depression in HIV | Psychother Res | Berg, C.; Raminani, S.; Greer, J.; Harwood, M.; Safren, S. | N<10
24517539 | Patient navigation facilitates medical and social services engagement among HIV-infected individuals leaving jail and returning to the community | AIDS Patient Care STDS | Koester, K. A.; Morewitz, M.; Pearson, C.; Weeks, J.; Packard, R.; Estes, M.; Tulsky, J.; Kang-Dufour, M. S.; Myers, J. J. | N<10
104599419. Language: | Patterns of Treatment Use and Barriers to Care Among Hospitalized Adults with HIV | Journal of HIV/AIDS & Social Services | Cavaleri, Mary A.; Elwyn, Laura; Pilgrim, Alicene; London, Karyn; Indyk, Debbie; Jackson, Jerrold; McKay, Mary M. | N<10
21050372 | Perceived Internet health literacy of HIV-positive people through the provision of a computer and Internet health education intervention | Health Info Libr J | Robinson, C.; Graham, J. | N<10
16436132 | Pilot study of interferon-alpha-ribavirin-interleukin-2 for treatment of nonresponder patients with severe liver disease infected by hepatitis C virus genotype 1 | J Viral Hepat | Alric, L.; Thebault, S.; Peron, J. M.; Balard, P.; Metivier, S.; Pipy, B.; Izopet, J.; Vinel, J. P. | N<10
19887287 | Positive self-management program for women living with HIV: a descriptive analysis | J Assoc Nurses AIDS Care | Webel, A. R.; Holzemer, W. L. | N<10
21350364 | Predictors of survival after a diagnosis of non-Hodgkin lymphoma in a resource-limited setting: a retrospective study on the impact of HIV infection and its treatment | J Acquir Immune Defic Syndr | Bateganya, M. H.; Stanaway, J.; Brentlinger, P. E.; Magaret, A. S.; Wald, A.; Orem, J.; Casper, C. | N<10
25711332 | Prevalence of and risk factors for low bone mineral density in untreated HIV infection: a substudy of the INSIGHT Strategic Timing of AntiRetroviral Treatment (START) trial | HIV Med | Carr, A.; Grund, B.; Neuhaus, J.; Schwartz, A.; Bernardino, J. I.; White, D.; Badel-Faesen, S.; Avihingsanon, A.; Ensrud, K.; Hoy, J. | N<10
16128897 | Prevalence of conditions associated with human immunodeficiency and hepatitis virus infections among persons with haemophilia, 2001-2003 | Haemophilia | Goedert, J. J. | N<10
15994147 | Prognostic factors and outcome of human herpesvirus 8-associated primary effusion lymphoma in patients with AIDS | J Clin Oncol | Boulanger, E.; Gerard, L.; Gabarre, J.; Molina, J. M.; Rapp, C.; Abino, J. F.; Cadranel, J.; Chevret, S.; Oksenhendler, E. | N<10
19178592 | Prolonged use of tenofovir in HIV/hepatitis B virus (HBV)-coinfected individuals does not lead to HBV polymerase mutations and is associated with persistence of lamivudine HBV polymerase mutations | HIV Med | Audsley, J.; Arrifin, N.; Yuen, L. K.; Ayres, A.; Crowe, S. M.; Bartholomeusz, A.; Locarnini, S. A.; Mijch, A.; Lewin, S. R.; Sasadeusz, J. | N<10
18243645 | Prospective memory in HIV infection: is ‘remembering to remember’ a unique predictor of self-reported medication management? | Arch Clin Neuropsychol | Woods, S. P.; Moran, L. M.; Carey, C. L.; Dawson, M. S.; Iudicello, J. E.; Gibson, S.; Grant, I.; Atkinson, J. H. | N<10
16231263 | Randomized study of the safety and efficacy of fish oil (omega-3 fatty acid) supplementation with dietary and exercise counseling for the treatment of antiretroviral therapy-associated hypertriglyceridemia | Clin Infect Dis | Wohl, D. A.; Tien, H. C.; Busby, M.; Cunningham, C.; Macintosh, B.; Napravnik, S.; Danan, E.; Donovan, K.; Hossenipour, M.; Simpson, R. J., Jr. | N<10
25331266 | Reliability and validity of daily self-monitoring by smartphone application for health-related quality-of-life, antiretroviral adherence, substance use, and sexual behaviors among people living with HIV | AIDS Behav | Swendeman, D.; Comulada, W. S.; Ramanathan, N.; Lazar, M.; Estrin, D. | N<10
21518940 | Risk of heart failure with human immunodeficiency virus in the absence of prior diagnosis of coronary heart disease | Arch Intern Med | Butt, A. A.; Chang, C. C.; Kuller, L.; Goetz, M. B.; Leaf, D.; Rimland, D.; Gibert, C. L.; Oursler, K. K.; Rodriguez-Barradas, M. C.; Lim, J.; Kazis, L. E.; Gottlieb, S.; Justice, A. C.; Freiberg, M. S. | N<10
23181946 | Risky decision-making in HIV-associated neurocognitive disorders (HAND) | Clin Neuropsychol | Iudicello, J. E.; Woods, S. P.; Cattie, J. E.; Doyle, K.; Grant, I. | N<10
17621464 | Safety and tolerability of sequential pegylated IFN-alpha2a and tenofovir for hepatitis B infection in HIV(+) individuals | HIV Clin Trials | Johnson, R. M.; Ristig, M. B.; Overton, E. T.; Lisker-Melman, M.; Cummings, O. W.; Aberg, J. A. | N<10
15963183 | Self-care strategies for depressive symptoms in people with HIV disease | J Adv Nurs | Eller, L. S.; Corless, I.; Bunch, E. H.; Kemppainen, J.; Holzemer, W.; Nokes, K.; Portillo, C.; Nicholas, P. | N<10
21909266 | Significant effects of antiretroviral therapy on global gene expression in brain tissues of patients with HIV-1-associated neurocognitive disorders | PLoS Pathog | Borjabad, A.; Morgello, S.; Chao, W.; Kim, S. Y.; Brooks, A. I.; Murray, J.; Potash, M. J.; Volsky, D. J. | N<10
24968746 | Sleeve gastrectomy is a safe and efficient procedure in HIV patients with morbid obesity: a case series with results in weight loss, comorbidity evolution, CD4 count, and viral load | Obes Surg | Fysekidis, M.; Cohen, R.; Bekheit, M.; Chebib, J.; Boussairi, A.; Bihan, H.; Khuong, M. A.; Finkielsztejn, L.; Mendoza, G.; Abgrall, S.; Conde, D.; Catheline, J. M. | N<10
18688212 | Smoked medicinal cannabis for neuropathic pain in HIV: a randomized, crossover clinical trial | Neuropsychop harmacology | Ellis, R. J.; Toperoff, W.; Vaida, F.; van den Brande, G.; Gonzales, J.; Gouaux, B.; Bentley, H.; Atkinson, J. H. | N<10
15647105 | Substituting abacavir for hyperlipidemia-associated protease inhibitors in HAART regimens improves fasting lipid profiles, maintains virologic suppression, and simplifies treatment | BMC Infect Dis | Keiser, P. H.; Sension, M. G.; DeJesus, E.; Rodriguez, A.; Olliffe, J. F.; Williams, V. C.; Wakeford, J. H.; Snidow, J. W.; Shachoy-Clark, A. D.; Fleming, J. W.; Pakes, G. E.; Hernandez, J. E. | N<10
21165783 | Successful cognitive aging in persons living with HIV infection | J Neurovirol | Malaspina, L.; Woods, S. P.; Moore, D. J.; Depp, C.; Letendre, S. L.; Jeste, D.; Grant, I. | N<10
17597712 | The effect of lopinavir/ritonavir on the renal clearance of tenofovir in HIV-infected patients | Clin Pharmacol Ther | Kiser, J. J.; Carten, M. L.; Aquilante, C. L.; Anderson, P. L.; Wolfe, P.; King, T. M.; Delahunty, T.; Bushman, L. R.; Fletcher, C. V. | N<10
19318998 | The impact of integrated HIV care on patient health outcomes | Med Care | Hoang, T.; Goetz, M. B.; Yano, E. M.; Rossman, B.; Anaya, H. D.; Knapp, H.; Korthuis, P. T.; Henry, R.; Bowman, C.; Gifford, A.; Asch, S. M. | N<10
24809827 | Visual function assessment in simulated real-life situations in HIV-infected subjects | PLoS One | Barteselli, G.; Chhablani, J.; Gomez, M. L.; Doede, A. L.; Dustin, L.; Kozak, I.; Bartsch, D. U.; Azen, S. P.; Letendre, S. L.; Freeman, W. R. | N<10
25290556 | Effect of a smartphone application incorporating personalized health-related imagery on adherence to antiretroviral therapy: a randomized clinical trial | AIDS Patient Care STDS | Perera, A. I.; Thomas, M. G.; Moore, J. O.; Faasse, K.; Petrie, K. J. | N<10
25229298 | Ventriculoperitoneal shunts for treating increased intracranial pressure in cryptococcal meningitis with or without ventriculomegaly | Rev Soc Bras Med Trop | Corti, M.; Priarone, M.; Negroni, R.; Gilardi, L.; Castrelo, J.; Arechayala, A. I.; Messina, F.; Franze, O. | N<10
22428809 | HealthCall: technology-based extension of motivational interviewing to reduce non-injection drug use in HIV primary care patients - a pilot study | AIDS Care | Aharonovich, E.; Greenstein, E.; O'Leary, A.; Johnston, B.; Seol, S. G.; Hasin, D. S. | N<10
19521118 | Clinical presentation and outcome of colorectal cancer in HIV-positive patients: a clinical case-control study | Onkologie | Berretta, M.; Cappellani, A.; Di Benedetto, F.; Lleshi, A.; Talamini, R.; Canzonieri, V.; Zanet, E.; Bearz, A.; Nasti, G.; Lacchin, T.; Berretta, S.; Fisichella, R.; Balestreri, L.; Torresin, A.; Izzi, I.; Ortolani, P.; Tirelli, U. | N<10
20959530 | Exercise training augments the peripheral insulin-sensitizing effects of pioglitazone in HIV-infected adults with insulin resistance and central adiposity | Am J Physiol Endocrinol Metab | Yarasheski, K. E.; Cade, W. T.; Overton, E. T.; Mondy, K. E.; Hubert, S.; Laciny, E.; Bopp, C.; Lassa-Claxton, S.; Reeds, D. N. | N<10
16870714 | Influence of increased CD4 cell counts on the genetic variability of hepatitis C virus in patients co-infected with human immunodeficiency virus I | J Biomol Tech | Wang, X. P.; Goodwin, L.; Kahn, P.; Gawel, C.; Cunha, C. B.; Laser, B.; Sahn, B.; Kaplan, M. H. | N<10
19444662 | MOMS: formative evaluation and subsequent intervention for mothers living with HIV | AIDS Care | Davies, S. L.; Horton, T. V.; Williams, A. G.; Martin, M. Y.; Stewart, K. E. | N<10
24134855 | The feasibility, acceptance, and key features of a prevention-focused oral health education program for HIV+ adults | AIDS Care | Vernon, L. T.; Demko, C. A.; Webel, A. R.; Mizumoto, R. M. | N<10
2010-07598-001 | The innocence of my country: An older Puerto Rican woman living with AIDS | Journal of Loss and Trauma | Carrion, Iraida V. | N<10
16908229 | Substance abuse, medications, HIV, and the community | Nurs Clin North Am | Vaughn, A. | N<10
16113597 | Deep subcutaneous application of poly-L-lactic acid as a filler for facial lipoatrophy in HIV-infected patients | Skin Pharmacol Physiol | Borelli, C.; Kunte, C.; Weisenseel, P.; Thoma-Greber, E.; Korting, H. C.; Konz, B. | N<10
17632936 | HIV-TB: a perfect storm | AIDS Read | Yoon, C. J. | N<10
18288976 | Coronary artery bypass graft in HIV-infected patients: a multicenter case control study | Curr HIV Res | Boccara, F.; Cohen, A.; Di Angelantonio, E.; Meuleman, C.; Ederhy, S.; Dufaitre, G.; Odi, G.; Teiger, E.; Barbarini, G.; Barbaro, G. | N<10
19430096 | Effect of antiviral treatment on serum markers of liver fibrosis in HIV-hepatitis C virus-coinfected patients: the Fibrovic 2 Study - ANRS HC02 | Antivir Ther | Halfon, P.; Carrat, F.; Bedossa, P.; Lambert, J.; Penaranda, G.; Perronne, C.; Pol, S.; Cacoub, P. | N<10
20163347 | In patients with HIV-infection, chromium supplementation improves insulin resistance and other metabolic abnormalities: a randomized, double-blind, placebo controlled trial | Curr HIV Res | Aghdassi, E.; Arendt, B. M.; Salit, I. E.; Mohammed, S. S.; Jalali, P.; Bondar, H.; Allard, J. P. | N<10
22443402 | Understanding and addressing stigma and attachment insecurity in HIV-positive women who experience intimate partner violence: a model of medical and psychosocial care | Soc Work Health Care | Davis, K. B. | N<10
22591357 | Minority HIV patients' perceptions of barriers and facilitators to participation in clinical research | Curr HIV Res | Wolak, C.; Bass, S. B.; Tedaldi, E.; Vandenburg-Wolf, M.; Rohrer, C. | N<10
22849960 | A pilot, prospective, open-label simplification study to evaluate the safety, efficacy, and pharmacokinetics of once-daily lopinavir-ritonavir monotherapy in HIV-HCV coinfected patients: the MONOCO study | HIV Clin Trials | Cooper, C.; la Porte, C.; Tossonian, H.; Sampalis, J.; Ackad, N.; Conway, B. | N<10
25143025 | Citalopram for the prevention of depression and its consequences in HIV-hepatitis C coinfected individuals initiating pegylated interferon/ribavirin therapy: a multicenter randomized double-blind placebo-controlled trial | HIV Clin Trials | Klein, M. B.; Lee, T.; Brouillette, M. J.; Sheehan, N. L.; Walmsley, S.; Wong, D. K.; Conway, B.; Hull, M.; Cooper, C.; Haidar, S.; Vezina, S.; Annable, L.; Young, S.; Zubyk, W.; Singer, J. | N<10
25615004 | Influence of treatment complexity on adherence and incidence of blips in HIV/HCV coinfected patients | J Manag Care Spec Pharm | Calvo-Cidoncha, E.; Gonzalez-Bueno, J.; Almeida-Gonzalez, C. V.; Morillo-Verdugo, R. | N<10
103956000. Language: | Colorectal Cancer Screening at the Nexus of HIV, Minority Statuses, and Cultural Safety | American Journal of Health Education | Ka'opua, Lana Sue I.; Diaz, Tressa P.; Park, Soon H.; Bowen, Talita; Patrick, Kevin; Tamang, Suresh; Braun, Kathryn L. | N<10
17956830 | Evolution of genotypic resistance algorithms and their impact on the interpretation of clinical trials: an OPTIMA trial substudy | HIV Clin Trials | Desai, S.; Kyriakides, T.; Holodniy, M.; Al-Salman, J.; Griffith, B.; Kozal, M. | N<10
104390477. Language: | A qualitative study of HIV serodiscordant patients accessing assisted reproductive treatment | Journal of Reproductive & Infant Psychology | Peak, Suellen A.; Nowoweiski, Sarah J.; Giles, Michelle L. | N<10
106274411. Language: | Empowerment: the evolving nature of the relationship between HIV/AIDS patients and their physicians | Journal of HIV/AIDS & Social Services | Reeves, P. M.; Arnold, T. G. | N<10
106251434. Language: | Exploring care access issues for Mexican-origin Latinos living with HIV in the San Diego/Tijuana border region | Journal of HIV/AIDS & Social Services | Zuniga, M. L.; Organista, K. C.; Scolari, R.; Olshefsky, A. M.; Schulhof, R.; ColÃ³n, M. | N<10
105613440. Language: | HIV/AIDS education in Harlem, New York: needs and recommendations | Journal of HIV/AIDS & Social Services | Beckerman, N. L.; Auerbach, C. | N<10
25867783 | Smartphone self-monitoring to support self-management among people living with HIV: perceived benefits and theory of change from a mixed-methods randomized pilot study | J Acquir Immune Defic Syndr | Swendeman, D.; Ramanathan, N.; Baetscher, L.; Medich, M.; Scheffler, A.; Comulada, W. S.; Estrin, D. | N<10
105330907. Language: | Supporting family stability: case studies in custody planning with HIV-affected families | Journal of HIV/AIDS & Social Services | Mason, S.; Vazquez, D. | N<10
79124260 | The Co-Occurrence of Mental Illness and High HIV Risk in a Sample of African American MSM: Findings and Implications | Journal of HIV/AIDS & Social Services | Loue, Sana; Daugherty-Brownrigg, Brittany; Heaphy, Emily; Mendez, Nancy; Sajatovic, Martha | N<10
16504957 | Treatment of condylomata acuminata with pegylated interferon alfa-2b in HIV-infected patients | Eur J Med Res | Brockmeyer, N. H.; Poffhoff, A.; Bader, A.; Hochdorfer, B.; Schlottmann, R.; Rasokat, H.; Altmeyer, P.; Kreuter, A. | N<10
104451610. Language: | Evaluation of Human Immunodeficiency Virus and Hepatitis C Telemedicine Clinics | American Journal of Managed Care | Saifu, Hemen N.; Asch, Steven M.; Goetz, Matthew Bidwell; Smith, Jason P.; Graber, Christopher J.; Schaberg, Dennis; Sun, Benjamin C. | N<10
51901565 | A Qualitative Study of Providers' Perception of Adherence of Women Living with HIV/AIDS in Puerto Rico | Qualitative Report | Rivero-Mendez, Marta; Dawson-Rose, Carol S.; SolÃs-BÃ¡ez, Solymar S. | N<10
16831783 | A low-cost, sustainable intervention for drinking reduction in the HIV primary care setting | AIDS Care | Aharonovich, E.; Hatzenbuehler, M. L.; Johnston, B.; O'Leary, A.; Morgenstern, J.; Wainberg, M. L.; Yao, P.; Helzer, J. E.; Hasin, D. S. | N<10
16971295 | A randomized controlled psycho-education intervention trial: Improving psychological readiness for successful HIV medication adherence and reducing depression before initiating HAART | AIDS Care | Balfour, L.; Kowal, J.; Silverman, A.; Tasca, G. A.; Angel, J. B.; Macpherson, P. A.; Garber, G.; Cooper, C. L.; Cameron, D. W. | N<10
17064331 | Health promotion for women with human immunodeficiency virus or acquired immunodeficiency syndrome | Journal of the American Academy of Nurse Practitioners | Abel, E.; Hopson, L.; Delville, C. | N<10
17482212 | The HIV Dementia Scale: predictive power in mild dementia and HAART | J Neurol Sci | Bottiggi, K. A.; Chang, J. J.; Schmitt, F. A.; Avison, M. J.; Mootoor, Y.; Nath, A.; Berger, J. R. | N<10
16048887 | The politics of invisibility: homophobia and low-income HIV-positive women who have sex with women | J Homosex | Arend, E. D. | N<10
20530469 | A dedicated screening program for geriatric HIV-infected patients integrating HIV and geriatric care | J Int Assoc Physicians AIDS Care (Chic) | Ruiz, M.; Cefalu, C.; Ogbuokiri, J. | N<10
22425919 | A phase I trial of the HIV protease inhibitor nelfinavir with concurrent chemoradiotherapy for unresectable stage IIIA/IIIB non-small cell lung cancer: a report of toxicities and clinical response | J Thorac Oncol | Rengan, R.; Mick, R.; Pryma, D.; Rosen, M. A.; Lin, L. L.; Maity, A. M.; Evans, T. L.; Stevenson, J. P.; Langer, C. J.; Kucharczuk, J.; Friedberg, J.; Prendergast, S.; Sharkoski, T.; Hahn, S. M. | N<10
22732025 | A pilot study of delivering peer health messages in an HIV clinic via mobile media | Telemed J E Health | Winstead-Derlega, C.; Rafaly, M.; Delgado, S.; Freeman, J.; Cutitta, K.; Miles, T.; Ingersoll, K.; Dillingham, R. | N<10
25064217 | A retrospective analysis of ten symptomatic multiple myeloma patients with HIV infection: a potential therapeutic effect of HAART in multiple myeloma | Leuk Res | Li, G.; Lewis, R. D.; Mishra, N.; Axiotis, C. A. | N<10
15899316 | Adherence, stereotyping and unequal HIV treatment for active users of illegal drugs | Soc Sci Med | Ware, N. C.; Wyatt, M. A.; Tugenberg, T. | N<10
18191766 | African American women's experience of infection with HIV in the rural southeastern United States | J Assoc Nurses AIDS Care | Mallory, C. | N<10
25149413 | Aging with HIV: a model of disability | J Int Assoc Provid AIDS Care | Solomon, P.; O'Brien, K.; Wilkins, S.; Gervais, N. | N<10
15598977 | Angiogenesis inhibitor IM862 is ineffective against AIDS-Kaposi's sarcoma in a phase III trial, but demonstrates sustained, potent effect of highly active antiretroviral therapy: from the AIDS Malignancy Consortium and IM862 Study Team | J Clin Oncol | Noy, A.; Scadden, D. T.; Lee, J.; Dezube, B. J.; Aboulafia, D.; Tulpule, A.; Walmsley, S.; Gill, P. | N<10
22820791 | Arterial inflammation in patients with HIV | Jama | Subramanian, S.; Tawakol, A.; Burdo, T. H.; Abbara, S.; Wei, J.; Vijayakumar, J.; Corsini, E.; Abdelbaky, A.; Zanni, M. V.; Hoffmann, U.; Williams, K. C.; Lo, J.; Grinspoon, S. K. | N<10
21323566 | Assessing the effectiveness of pharmacy-based adherence interventions on antiretroviral adherence in persons with HIV | AIDS Patient Care STDS | Henderson, K. C.; Hindman, J.; Johnson, S. C.; Valuck, R. J.; Kiser, J. J. | N<10
21113849 | Barriers to HIV care: an exploration of the complexities that influence engagement in and utilization of treatment | Soc Work Health Care | Cavaleri, M. A.; Kalogerogiannis, K.; McKay, M. M.; Vitale, L.; Levi, E.; Jones, S.; Wallach, F.; Flynn, E. | N<10
23363655 | Birthplace, culture, self-esteem, and intimate partner violence among community-dwelling Hispanic women | Violence Against Women | Gonzalez-Guarda, R. M.; Vermeesch, A. L.; Florom-Smith, A. L.; McCabe, B. E.; Peragallo, N. P. | N<10
22938914 | Brief versus extended counseling along with buprenorphine/naloxone for HIV-infected opioid dependent patients | J Subst Abuse Treat | Tetrault, J. M.; Moore, B. A.; Barry, D. T.; O'Connor, P. G.; Schottenfeld, R.; Fiellin, D. A.; Fiellin, L. E. | N<10
23018443 | Cerebral beta-amyloid deposition predicts HIV-associated neurocognitive disorders in APOE epsilon4 carriers | Aids | Soontornniyomkij, V.; Moore, D. J.; Gouaux, B.; Soontornniyomkij, B.; Tatro, E. T.; Umlauf, A.; Masliah, E.; Levine, A. J.; Singer, E. J.; Vinters, H. V.; Gelman, B. B.; Morgello, S.; Cherner, M.; Grant, I.; Achim, C. L. | N<10
22614889 | Cerebrospinal fluid HIV escape associated with progressive neurologic dysfunction in patients on antiretroviral therapy with well controlled plasma viral load | Aids | Peluso, M. J.; Ferretti, F.; Peterson, J.; Lee, E.; Fuchs, D.; Boschini, A.; Gisslen, M.; Angoff, N.; Price, R. W.; Cinque, P.; Spudich, S. | N<10
25466320 | Characteristics and outcomes of HIV-1-infected patients with acute respiratory distress syndrome | J Crit Care | Nirappil, F. J.; Maheshwari, A.; Andrews, J.; Martin, G. S.; Esper, A. M.; Cribbs, S. K. | N<10
21710235 | Characteristics of colorectal cancer in the human immunodeficiency virus-infected African American population | Med Oncol | Kumar, A.; Shah, N.; Modi, Y.; Shaaban, H. S.; DePasquale, J.; DeBari, V. A.; Yerrabothala, S.; Maroules, M.; Guron, G. K. | N<10
22995189 | Characterization of anti-HIV-1 neutralizing and binding antibodies in chronic HIV-1 subtype C infection | Virology | Archary, D.; Rong, R.; Gordon, M. L.; Boliar, S.; Madiga, M.; Gray, E. S.; Dugast, A. S.; Hermanus, T.; Goulder, P. J.; Coovadia, H. M.; Werner, L.; Morris, L.; Alter, G.; Derdeyn, C. A.; Ndung'u, T. | N<10
20386424 | Clearance of hepatitis C virus RNA from serum in HIV/hepatitis C virus coinfection indicates eradication from peripheral blood mononuclear cells | Aids | Page, E. E.; Cox, A.; Atkins, M.; Nelson, M. R. | N<10
23848504 | Clinical outcome and predictors of survival in patients with pneumocystis jirovecii pneumonia--results of a tertiary referral centre | Clin Respir J | Roembke, F.; Heinzow, H. S.; Gosseling, T.; Heinecke, A.; Domagk, D.; Domschke, W.; Meister, T. | N<10
18607714 | Cognitive adaptability as a moderator of expressive writing effects in an HIV sample | AIDS Behav | Wagner, L. J.; Hilker, K. A.; Hepworth, J. T.; Wallston, K. A. | N<10
19744801 | Concurrent chemoradiotherapy with 5-fluorouracil and mitomycin C for invasive anal carcinoma in human immunodeficiency virus-positive patients receiving highly active antiretroviral therapy | Int J Radiat Oncol Biol Phys | Fraunholz, I.; Weiss, C.; Eberlein, K.; Haberl, A.; Rodel, C. | N<10
21762990 | Conjunctival squamous cell carcinoma arising in immunosuppressed patients (organ transplant, human immunodeficiency virus infection) | Ophthalmology | Shields, C. L.; Ramasubramanian, A.; Mellen, P. L.; Shields, J. A. | N<10
23922644 | Cortisol patterns are associated with T cell activation in HIV | PLoS One | Patterson, S.; Moran, P.; Epel, E.; Sinclair, E.; Kemeny, M. E.; Deeks, S. G.; Bacchetti, P.; Acree, M.; Epling, L.; Kirschbaum, C.; Hecht, F. M. | N<10
21488192 | Cryptococcal meningitis in patients with or without human immunodeficiency virus: experience in a tertiary hospital | Yonsei Med J | Lee, S. J.; Choi, H. K.; Son, J.; Kim, K. H.; Lee, S. H. | N<10
15768348 | Delivering care to injection drug users coinfected with HIV and hepatitis C virus | Clin Infect Dis | Taylor, L. E. | N<10
22242700 | Developing a modified directly observed therapy intervention for hepatitis C treatment in a methadone maintenance program: implications for program replication | Am J Drug Alcohol Abuse | Bruce, R. D.; Eiserman, J.; Acosta, A.; Gote, C.; Lim, J. K.; Altice, F. L. | N<10
23230862 | Developing PeerLink to engage out-of-care HIV+ substance users: training peers to deliver a peer-led motivational intervention with fidelity | AIDS Care | Wolfe, H.; Haller, D. L.; Benoit, E.; Bolger, K. W.; Cancienne, J. C.; Ingersoll, K. S.; Sharp, V. | N<10
19538046 | Development of an electronic medical record-based clinical decision support tool to improve HIV symptom management | AIDS Patient Care STDS | Nader, C. M.; Tsevat, J.; Justice, A. C.; Mrus, J. M.; Levin, F.; Kozal, M. J.; Mattocks, K.; Farber, S.; Rogers, M.; Erdos, J.; Brandt, C.; Kudel, I.; Braithwaite, R. | N<10
22823125 | Differential effect of alcoholism and HIV infection on visuomotor procedural learning and retention | Alcohol Clin Exp Res | Fama, R.; Rosenbloom, M. J.; Sassoon, S. A.; Pfefferbaum, A.; Sullivan, E. V. | N<10
23007110 | Directly administered antiretroviral therapy: pilot study of a structural intervention in methadone maintenance | J Subst Abuse Treat | Sorensen, J. L.; Haug, N. A.; Larios, S.; Gruber, V. A.; Tulsky, J.; Powelson, E.; Logan, D. P.; Shapiro, B. | N<10
22720766 | Directly observed antidepressant medication treatment and HIV outcomes among homeless and marginally housed HIV-positive adults: a randomized controlled trial | Am J Public Health | Tsai, A. C.; Karasic, D. H.; Hammer, G. P.; Charlebois, E. D.; Ragland, K.; Moss, A. R.; Sorensen, J. L.; Dilley, J. W.; Bangsberg, D. R. | N<10
104235575. Language: | Does Effective Depression Treatment Alone Reduce Secondary HIV Transmission Risk? Equivocal Findings from a Randomized Controlled Trial | AIDS & Behavior | Tsai, Alexander; Mimiaga, Matthew; Dilley, James; Hammer, Gwendolyn; Karasic, Dan; Charlebois, Edwin; Sorensen, James; Safren, Steven; Bangsberg, David | N<10
26512601 | Dynamic of Mixed HCV Infection in Plasma and PBMC of HIV/HCV Patients Under Treatment With Peg-IFN/Ribavirin | Medicine (Baltimore) | Bagaglio, S. | N<10
22431997 | Dynamics of adrenal steroids are related to variations in Th1 and Treg populations during Mycobacterium tuberculosis infection in HIV positive persons | PLoS One | Quiroga, M. F.; Angerami, M. T.; Santucci, N.; Ameri, D.; Francos, J. L.; Wallach, J.; Sued, O.; Cahn, P.; Salomon, H.; Bottasso, O. | N<10
23944194 | Effect of armodafinil on cognition in patients with HIV/AIDS and fatigue | J Clin Exp Neuropsychol | McElhiney, M.; Rabkin, J.; Van Gorp, W.; Rabkin, R. | N<10
18275348 | Effect of low-dose IL-2 immunotherapy on frequency and phenotype of regulatory T cells and NK cells in HIV/HCV-coinfected patients | AIDS Res Hum Retroviruses | Velilla, P. A.; Shata, M. T.; Lages, C. S.; Ying, J.; Fichtenbaum, C. J.; Chougnet, C. | N<10
22606304 | Effect of standard tuberculosis treatment on plasma cytokine levels in patients with active pulmonary tuberculosis | PLoS One | Riou, C.; Perez Peixoto, B.; Roberts, L.; Ronacher, K.; Walzl, G.; Manca, C.; Rustomjee, R.; Mthiyane, T.; Fallows, D.; Gray, C. M.; Kaplan, G. | N<10
16283835 | Effects of a treatment adherence enhancement program on health literacy, patient-provider relationships, and adherence to HAART among low-income HIV-positive Spanish-speaking Latinos | AIDS Patient Care STDS | van Servellen, G.; Nyamathi, A.; Carpio, F.; Pearce, D.; Garcia-Teague, L.; Herrera, G.; Lombardi, E. | N<10
16979511 | Effects of ice massage on neuropathic pain in persons with AIDS | J Assoc Nurses AIDS Care | Ownby, K. K. | N<10
21180864 | Effects of physical exercise in the perception of life satisfaction and immunological function in HIV-infected patients: Non-randomized clinical trial | Rev Bras Fisioter | Gomes, R. D.; Borges, J. P.; Lima, D. B.; Farinatti, P. T. | N<10
18753861 | Efficacy and safety of entecavir for chronic HBV in HIV/HBV coinfected patients receiving lamivudine as part of antiretroviral therapy | Aids | Pessoa, M. G.; Gazzard, B.; Huang, A. K.; Brandao-Mello, C. E.; Cassetti, I.; Mendes-Correa, M. C.; Soriano, V.; Phiri, P.; Hall, A.; Brett-Smith, H. | N<10
25469527 | Elvitegravir/cobicistat/emtricitabine/tenofovir DF in HIV-infected patients with mild-to-moderate renal impairment | J Acquir Immune Defic Syndr | Post, F. A.; Winston, J.; Andrade-Villanueva, J. F.; Fisher, M.; Liu, Y.; Beraud, C.; Abram, M. E.; Graham, H.; Rhee, M. S.; Cheng, A. K.; Szwarcberg, J. | N<10
17393948 | Enrollment of racial/ethnic minorities and women with HIV in clinical research studies of HIV medicines | J Natl Med Assoc | Sullivan, P. S.; McNaghten, A. D.; Begley, E.; Hutchinson, A.; Cargill, V. A. | N<10
104245666. Language: | Evaluation of an HIV Prevention Intervention Designed for African American Women: Results from the SISTA Community-Based Organization Behavioral Outcomes Project | AIDS & Behavior | Sapiano, Tobey; Moore, A.; Kalayil, E.; Zhang, X.; Chen, B.; Uhl, G.; Patel-Larson, A.; Williams, W. | N<10
22440043 | Examining barriers to care: provider and client perspectives on the stigmatization of HIV-positive Asian Americans with and without viral hepatitis co-infection | AIDS Care | Russ, L. W.; Meyer, A. C.; Takahashi, L. M.; Ou, S.; Tran, J.; Cruz, P.; Magalong, M.; Candelario, J. | N<10
23428205 | Factors contributing to dropping out from and returning to HIV treatment in an inner city primary care HIV clinic in the United States | AIDS Care | Pecoraro, A.; Royer-Malvestuto, C.; Rosenwasser, B.; Moore, K.; Howell, A.; Ma, M.; Woody, G. E. | N<10
19929229 | Factors that influence an HIV coinfected patient's decision to start hepatitis C treatment | AIDS Patient Care STDS | Osilla, K. C.; Ryan, G.; Bhatti, L.; Goetz, M.; Witt, M.; Wagner, G. | N<10
21328144 | Feasibility of telephone-based cognitive behavioral therapy targeting major depression among urban dwelling African-American people with co-occurring HIV | Psychol Health Med | Himelhoch, S.; Mohr, D.; Maxfield, J.; Clayton, S.; Weber, E.; Medoff, D.; Dixon, L. | N<10
18229435 | Frequency, severity and duration of immune reconstitution events in HIV-related tuberculosis | Int J Tuberc Lung Dis | Burman, W.; Weis, S.; Vernon, A.; Khan, A.; Benator, D.; Jones, B.; Silva, C.; King, B.; LaHart, C.; Mangura, B.; Weiner, M.; El-Sadr, W. | N<10
24249700 | GBV-C viremia and clinical events in advanced HIV infection | J Med Virol | Sahni, H.; Kirkwood, K.; Kyriakides, T. C.; Stapleton, J.; Brown, S. T.; Holodniy, M. | N<10
21257738 | Genetic variation in IL28B and treatment-induced clearance of hepatitis C virus in HIV-positive patients with acute and chronic hepatitis C | J Infect Dis | Nattermann, J.; Vogel, M.; Nischalke, H. D.; Danta, M.; Mauss, S.; Stellbrink, H. J.; Baumgarten, A.; Mayr, C.; Bruno, R.; Tural, C.; Klausen, G.; Clotet, B.; Naumann, U.; Lutz, T.; Rausch, M.; Schewe, K.; Bienek, B.; Haerter, G.; Sauerbruch, T.; Rockstroh, J. K.; Spengler, U. | N<10
25354736 | Health Literacy in HIV Treatment: Accurate Understanding of Key Biological Treatment Principles is Not Required for Good ART Adherence | AIDS & Behavior | Laws, M.; Danielewicz, Michael; Rana, Aadia; Kogelman, Laura; Wilson, Ira | N<10
19295332 | Health-related quality of life in a randomized trial of antiretroviral therapy for advanced HIV disease | J Acquir Immune Defic Syndr | Joyce, V. R.; Barnett, P. G.; Bayoumi, A. M.; Griffin, S. C.; Kyriakides, T. C.; Yu, W.; Sundaram, V.; Holodniy, M.; Brown, S. T.; Cameron, W.; Youle, M.; Sculpher, M.; Anis, A. H.; Owens, D. K. | N<10
19560693 | Heart transplantation in human immunodeficiency virus-positive patients | J Heart Lung Transplant | Uriel, N.; Jorde, U. P.; Cotarlan, V.; Colombo, P. C.; Farr, M.; Restaino, S. W.; Lietz, K.; Naka, Y.; Deng, M. C.; Mancini, D. | N<10
15710216 | Hepatitis C virus viral recurrence and liver mitochondrial damage after liver transplantation in HIV-HCV co-infected patients | J Hepatol | Duclos-Vallee, J. C.; Vittecoq, D.; Teicher, E.; Feray, C.; Roque-Afonso, A. M.; Lombes, A.; Jardel, C.; Gigou, M.; Dussaix, E.; Sebagh, M.; Guettier, C.; Azoulay, D.; Adam, R.; Ichai, P.; Saliba, F.; Roche, B.; Castaing, D.; Bismuth, H.; Samuel, D. | N<10
18293136 | HIV patient insight on adhering to medication: a qualitative analysis | AIDS Care | Beusterien, K. M.; Davis, E. A.; Flood, R.; Howard, K.; Jordan, J. | N<10
104385173. Language: | HIV Status Does Not Influence Outcome in Patients With Classical Hodgkin Lymphoma Treated With Chemotherapy Using Doxorubicin, Bleomycin, Vinblastine, and Dacarbazine in the Highly Active Antiretroviral Therapy Era | Journal of Clinical Oncology | Montoto, S.; Shaw, K.; Okosun, J.; Gandhi, S.; Fields, P.; Wilson, A.; Shanyinde, M.; Cwynarski, K.; Marcus, R.; de Vos, J.; Young, A. M.; Tenant-Flowers, M.; Orkin, C.; Johnson, M.; Chilton, D.; Gribben, J. G.; Bower, M. | N<10
105796379. Language: | HIV-specific differences in outcome of squamous cell carcinoma of the anal canal: a multicentric cohort study of HIV-positive patients receiving highly active antiretroviral therapy | Journal of Clinical Oncology | Oehler-JÃ¤nne, C.; Huguet, F.; Provencher, S.; Seifert, B.; Negretti, L.; Riener, M.; Bonet, M.; Allal, A. S.; Ciernik, I. F. | N<10
2011-02382-009 | I'm not going to die from the AIDS': Resilience in aging with HIV disease | The Gerontologist | Emlet, Charles A.; Tozay, Shakima; Raveis, Victoria H. | N<10
25831464 | Immune Reconstitution in Severely Immunosuppressed Antiretroviral-Naive HIV-1-Infected Patients Starting Efavirenz, Lopinavir-Ritonavir, or Atazanavir-Ritonavir Plus Tenofovir/Emtricitabine: Final 48-Week Results (The Advanz-3 Trial) | J Acquir Immune Defic Syndr | Miro, J. M.; Manzardo, C.; Ferrer, E.; Lonca, M.; Guardo, A. C.; Podzamczer, D.; Domingo, P.; Curran, A.; Clotet, B.; Cruceta, A.; Lozano, F.; Perez, I.; Plana, M.; Gatell, J. M. | N<10
17342655 | Impact of hepatitis D virus infection on the long-term outcomes of patients with hepatitis B virus and HIV coinfection in the era of highly active antiretroviral therapy: a matched cohort study | Clin Infect Dis | Sheng, W. H.; Hung, C. C.; Kao, J. H.; Chang, S. Y.; Chen, M. Y.; Hsieh, S. M.; Chen, P. J.; Chang, S. C. | N<10
25377444 | Impact of minocycline on cerebrospinal fluid markers of oxidative stress, neuronal injury, and inflammation in HIV-seropositive individuals with cognitive impairment | J Neurovirol | Sacktor, N.; Miyahara, S.; Evans, S.; Schifitto, G.; Cohen, B.; Haughey, N.; Drewes, J. L.; Graham, D.; Zink, M. C.; Anderson, C.; Nath, A.; Pardo, C. A.; McCarthy, S.; Hosey, L.; Clifford, D. | N<10
16269552 | Impact of tenofovir-containing antiretroviral therapy on chronic hepatitis B in a cohort co-infected with human immunodeficiency virus | J Antimicrob Chemother | Stephan, C.; Berger, A.; Carlebach, A.; Lutz, T.; Bickel, M.; Klauke, S.; Staszewski, S.; Stuermer, M. | N<10
19458009 | Impaired quality of the hepatitis B virus (HBV)-specific T-cell response in human immunodeficiency virus type 1-HBV coinfection | J Virol | Chang, J. J.; Sirivichayakul, S.; Avihingsanon, A.; Thompson, A. J.; Revill, P.; Iser, D.; Slavin, J.; Buranapraditkun, S.; Marks, P.; Matthews, G.; Cooper, D. A.; Kent, S. J.; Cameron, P. U.; Sasadeusz, J.; Desmond, P.; Locarnini, S.; Dore, G. J.; Ruxrungtham, K.; Lewin, S. R. | N<10
21778341 | Improved outcome with rituximab in patients with HIV-associated multicentric Castleman disease | Blood | Hoffmann, C.; Schmid, H.; Muller, M.; Teutsch, C.; van Lunzen, J.; Esser, S.; Wolf, T.; Wyen, C.; Sabranski, M.; Horst, H. A.; Reuter, S.; Vogel, M.; Jager, H.; Bogner, J.; Arasteh, K. | N<10
16940448 | Improved triglycerides and insulin sensitivity with 3 months of acipimox in human immunodeficiency virus-infected patients with hypertriglyceridemia | J Clin Endocrinol Metab | Hadigan, C.; Liebau, J.; Torriani, M.; Andersen, R.; Grinspoon, S. | N<10
25125679 | Improvement in bone mineral density after switching from tenofovir to abacavir in HIV-1-infected patients with low bone mineral density: two-centre randomized pilot study (OsteoTDF study) | J Antimicrob Chemother | Negredo, E.; Domingo, P.; Perez-Alvarez, N.; Gutierrez, M.; Mateo, G.; Puig, J.; Escrig, R.; Echeverria, P.; Bonjoch, A.; Clotet, B. | N<10
20693936 | Improving partner services by embedding disease intervention specialists in HIV-clinics | Sex Transm Dis | Taylor, M. M.; Mickey, T.; Winscott, M.; James, H.; Kenney, K.; England, B. | N<10
22234543 | Increased cortical expression of FK506 binding protein-51 in HIV-associated neurocognitive disorders | J Neurovirol | Soontornniyomkij, V.; Everall, I. P.; Moore, D. J.; Gouaux, B.; Tatro, E. T.; Gospodarev, V.; Masliah, E.; Yin, N. S.; Vinters, H. V.; Achim, C. L. | N<10
23523090 | Individual and neighborhood correlates of membership in drug using networks with a higher prevalence of HIV in New York City (2006-2009) | Ann Epidemiol | Rudolph, A. E.; Crawford, N. D.; Latkin, C.; Fowler, J. H.; Fuller, C. M. | N<10
106253556. Language: | Individual variability in barriers affecting people's decision to take HAART: a qualitative study identifying barriers to being on HAART | AIDS Patient Care & STDs | Alfonso, V.; Bermbach, N.; Geller, J.; Montaner, J. S. G. | N<10
15741629 | Infections of the spine in patients with human immunodeficiency virus | J Bone Joint Surg Am | Weinstein, M. A.; Eismont, F. J. | N<10
23299761 | Intensive lifestyle modification reduces Lp-PLA2 in dyslipidemic HIV/HAART patients | Med Sci Sports Exerc | Wooten, J. S.; Nambi, P.; Gillard, B. K.; Pownall, H. J.; Coraza, I.; Scott, L. W.; Nambi, V.; Ballantyne, C. M.; Balasubramanyam, A. | N<10
18097222 | Intrahepatic mRNA expression in hepatitis C virus and HIV/hepatitis C virus co-infection: infiltrating cells, cytokines, and influence of HAART | Aids | Kuntzen, T.; Tural, C.; Li, B.; Feldmann, G.; Kupfer, B.; Nischalke, H. D.; Clotet, B.; Sauerbruch, T.; Rockstroh, J. K.; Spengler, U. | N<10
18066626 | Invasive anal squamous-cell carcinoma in the HIV-positive patient: outcome in the era of highly active antiretroviral therapy | Dis Colon Rectum | Wexler, A.; Berson, A. M.; Goldstone, S. E.; Waltzman, R.; Penzer, J.; Maisonet, O. G.; McDermott, B.; Rescigno, J. | N<10
18614926 | Lipid and apoprotein profile in HIV-1-infected patients after CD4-guided treatment interruption | J Acquir Immune Defic Syndr | Seoane, E.; Resino, S.; Micheloud, D.; Moreno, A.; de Quiros, J. C.; Lorente, R.; Rubio, R.; Gonzalez, J.; Pulido, F.; Arribas, J. R.; Moreno, S.; Munoz-Fernandez, M. | N<10
104130331. Language: | Listening to Those Who are Living With HIV and Tobacco Dependence and Exploring Their Health Care Context | JANAC: Journal of the Association of Nurses in AIDS Care | Schultz, Annette S. H.; Temple, Beverley; Gibbons, Caitlan; Preston, Jocelyn; Ronson, Gillian | N<10
16954730 | Lithium improves HIV-associated neurocognitive impairment | Aids | Letendre, S. L.; Woods, S. P.; Ellis, R. J.; Atkinson, J. H.; Masliah, E.; van den Brande, G.; Durelle, J.; Grant, I.; Everall, I. | N<10
19306230 | Lithium therapy for human immunodeficiency virus type 1-associated neurocognitive impairment | J Neurovirol | Schifitto, G.; Zhong, J.; Gill, D.; Peterson, D. R.; Gaugh, M. D.; Zhu, T.; Tivarus, M.; Cruttenden, K.; Maggirwar, S. B.; Gendelman, H. E.; Dewhurst, S.; Gelbard, H. A. | N<10
22268972 | Living with HIV: responses to a mantram intervention using the critical incident research method | J Altern Complement Med | Kemppainen, J.; Bormann, J. E.; Shively, M.; Kelly, A.; Becker, S.; Bone, P.; Belding, W.; Gifford, A. L. | N<10
23276804 | Long-term effectiveness of infrared coagulation for the treatment of anal intraepithelial neoplasia grades 2 and 3 in HIV-infected men and women | Aids | Sirera, G.; Videla, S.; Pinol, M.; Coll, J.; Garcia-Cuyas, F.; Vela, S.; Canadas, M.; Darwich, L.; Perez, N.; Gel, S.; Cobarsi, P.; Clotet, B. | N<10
20024700 | Long-term efficacy and safety of polyalkylimide gel for the treatment of HIV-associated lipoatrophy | AIDS Care | Antoniou, T.; Raboud, J. M.; Kovacs, C.; Diong, C.; Brunetta, J.; Smith, G.; Halpenny, R.; Beninger, F.; Loutfy, M. R. | N<10
16682476 | Lymphatic tissue fibrosis is associated with reduced numbers of naive CD4+ T cells in human immunodeficiency virus type 1 infection | Clin Vaccine Immunol | Schacker, T. W.; Brenchley, J. M.; Beilman, G. J.; Reilly, C.; Pambuccian, S. E.; Taylor, J.; Skarda, D.; Larson, M.; Douek, D. C.; Haase, A. T. | N<10
25101888 | Modulation of HCV replication after combination antiretroviral therapy in HCV/HIV co-infected patients | Sci Transl Med | Sherman, K. E.; Guedj, J.; Shata, M. T.; Blackard, J. T.; Rouster, S. D.; Castro, M.; Feinberg, J.; Sterling, R. K.; Goodman, Z.; Aronow, B. J.; Perelson, A. S. | N<10
17852960 | Narrative slope as a predictor of work and other occupational participation | Scand J Occup Ther | Levin, M.; Kielhofner, G.; Braveman, B.; Fogg, L. | N<10
23221125 | Navigating hazardous conditions: understanding HIV medication adherence in the context of depression | Qual Health Res | Wendorf, A. R.; Mosack, K. E. | N<10
22020160 | No reduction of HCV viral load in HIV patients co-infected with HCV genotype 1 during a 30 days course of nitazoxanide monotherapy | Antiviral Res | Laufer, N.; Abusamra, L.; Bolcic, F.; Gun, A.; Rolon, M. J.; Perez, H.; Krolewiecki, A.; Salomon, H.; Quarleri, J.; Cahn, P. | N<10
18665246 | Not all missed doses are the same: sustained NNRTI treatment interruptions predict HIV rebound at low-to-moderate adherence levels | PLoS One | Parienti, J. J.; Das-Douglas, M.; Massari, V.; Guzman, D.; Deeks, S. G.; Verdon, R.; Bangsberg, D. R. | N<10
20024707 | Older African Americans' management of HIV/AIDS stigma | AIDS Care | Foster, P. P.; Gaskins, S. W. | N<10
109824737. Language: | Open Trial of an Acceptance-Based Behavior Therapy Intervention to Engage Newly Diagnosed HIV Patients in Care | Behavior Modification | Moitra, Ethan; Chan, Philip A.; Stein, Michael D. | N<10
23076663 | Outcome of HCV genotype 1 treatment in HIV-coinfected patients with chronic kidney disease | J Int Assoc Provid AIDS Care | Oppenheimer, A. P.; Johnson, J.; Nunez, M. | N<10
17893602 | Outcomes after orthotopic liver transplantation in 15 HIV-infected patients | Transplantation | Schreibman, I.; Gaynor, J. J.; Jayaweera, D.; Pyrsopoulos, N.; Weppler, D.; Tzakis, A.; Schiff, E. R.; Regev, A. | N<10
23683515 | Outcomes of total hip arthroplasty in human immunodeficiency virus-positive patients | J Arthroplasty | Snir, N.; Wolfson, T. S.; Schwarzkopf, R.; Swensen, S.; Alvarado, C. M.; Hamula, M.; Dayan, A. J. | N<10
16829361 | Palliative home nursing interventions for people with HIV/AIDS: a pilot study | J Assoc Nurses AIDS Care | Robinson, L.; Dugger, K.; Fong, G.; Heintzman, T.; Hnizdo, S.; Libby, J.; McDaniels, J.; Miles, J.; Rempel, H.; Taylor, A.; Warshaw, M. | N<10
22547879 | Patient perspectives on improving oral health-care practices among people living with HIV/AIDS | Public Health Rep | Rajabiun, S.; Fox, J. E.; McCluskey, A.; Guevara, E.; Verdecias, N.; Jeanty, Y.; DeMayo, M.; Mofidi, M. | N<10
105279405. Language: | Patients' perspectives on informal caregiver involvement in HIV health care appointments | AIDS Patient Care & STDs | Mosack, K. E.; Petroll, A. | N<10
18389361 | Patterns and correlates of sexual activity and condom use behavior in persons 50-plus years of age living with HIV/AIDS | AIDS Behav | Lovejoy, T. I.; Heckman, T. G.; Sikkema, K. J.; Hansen, N. B.; Kochman, A.; Suhr, J. A.; Garske, J. P.; Johnson, C. J. | N<10
17804348 | Peer support to promote medication adherence among people living with HIV/AIDS: the benefits to peers | Soc Work Health Care | Marino, P.; Simoni, J. M.; Silverstein, L. B. | N<10
21877204 | Performances on the CogState and standard neuropsychological batteries among HIV patients without dementia | AIDS Behav | Overton, E. T.; Kauwe, J. S.; Paul, R.; Tashima, K.; Tate, D. F.; Patel, P.; Carpenter, C. C.; Patty, D.; Brooks, J. T.; Clifford, D. B. | N<10
18716509 | PET/CT in the evaluation of lymphoma in patients with HIV-1 with suppressed viral loads | Clin Nucl Med | Goshen, E.; Davidson, T.; Avigdor, A.; Zwas, T. S.; Levy, I. | N<10
18224669 | Phase 1/2 trial of BMS-275291 in patients with human immunodeficiency virus-related Kaposi sarcoma: a multicenter trial of the AIDS Malignancy Consortium | Cancer | Brinker, B. T.; Krown, S. E.; Lee, J. Y.; Cesarman, E.; Chadburn, A.; Kaplan, L. D.; Henry, D. H.; Von Roenn, J. H. | N<10
22430271 | Phase II study of bevacizumab in patients with HIV-associated Kaposi's sarcoma receiving antiretroviral therapy | J Clin Oncol | Uldrick, T. S.; Wyvill, K. M.; Kumar, P.; O'Mahony, D.; Bernstein, W.; Aleman, K.; Polizzotto, M. N.; Steinberg, S. M.; Pittaluga, S.; Marshall, V.; Whitby, D.; Little, R. F.; Yarchoan, R. | N<10
104152064. Language: | Pilot Controlled Trial of the Adherence Readiness Program: An Intervention to Assess and Sustain HIV Antiretroviral Adherence Readiness | AIDS & Behavior | Wagner, Glenn; Lovely, Paul; Schneider, Stefan | N<10
21207228 | Pilot study evaluating the interaction between paclitaxel and protease inhibitors in patients with human immunodeficiency virus-associated Kaposi's sarcoma: an Eastern Cooperative Oncology Group (ECOG) and AIDS Malignancy Consortium (AMC) trial | Cancer Chemother Pharmacol | Cianfrocca, M.; Lee, S.; Von Roenn, J.; Rudek, M. A.; Dezube, B. J.; Krown, S. E.; Sparano, J. A. | N<10
25190222 | Positive Transitions (POST): Evaluation of an HIV Prevention Intervention for HIV-Positive Persons Releasing from Correctional Facilities | AIDS & Behavior | MacGowan, Robin; Lifshay, Julie; Mizuno, Yuko; Johnson, Wayne; McCormick, Lyle; Zack, Barry | N<10
16284455 | Presence of JC virus-specific CTL in the cerebrospinal fluid of PML patients: rationale for immune-based therapeutic strategies | Aids | Du Pasquier, R. A.; Autissier, P.; Zheng, Y.; Jean-Jacques, J.; Koralnik, I. J. | N<10
21553252 | Prevention needs of HIV-positive men and women awaiting release from prison | AIDS Behav | Catz, S. L.; Thibodeau, L.; BlueSpruce, J.; Yard, S. S.; Seal, D. W.; Amico, K. R.; Bogart, L. M.; Mahoney, C.; Balderson, B. H.; Sosman, J. M. | N<10
24493824 | Prognostic value of vitamin D level for all-cause mortality, and association with inflammatory markers, in HIV-infected persons | J Infect Dis | Shepherd, L.; Souberbielle, J. C.; Bastard, J. P.; Fellahi, S.; Capeau, J.; Reekie, J.; Reiss, P.; Blaxhult, A.; Bickel, M.; Leen, C.; Kirk, O.; Lundgren, J. D.; Mocroft, A.; Viard, J. P. | N<10
23078780 | Programming of neurotoxic cofactor CXCL-10 in HIV-1-associated dementia: abrogation of CXCL-10-induced neuro-glial toxicity in vitro by PKC activator | J Neuroinflammation | Mehla, R.; Bivalkar-Mehla, S.; Nagarkatti, M.; Chauhan, A. | N<10
18191771 | Promoting adaptive coping by persons with HIV disease: evaluation of a patient/partner intervention model | J Assoc Nurses AIDS Care | Fife, B. L.; Scott, L. L.; Fineberg, N. S.; Zwickl, B. E. | N<10
18506613 | Psychosocial correlates of unprotected sex without disclosure of HIV-positivity among African-American, Latino, and White men who have sex with men and women | Arch Sex Behav | Mutchler, M. G.; Bogart, L. M.; Elliott, M. N.; McKay, T.; Suttorp, M. J.; Schuster, M. A. | N<10
104648307. Language: | Qualitative Assessment of Barriers and Facilitators to HIV Treatment | JANAC: Journal of the Association of Nurses in AIDS Care | Williams, Bryman; Amico, K. Rivet; Konkle-Parker, Deborah | N<10
22246828 | Quantitation of hepatitis C virus RNA in peripheral blood mononuclear cells in HCV-monoinfection and HIV/HCV-coinfection | J Med Virol | Chary, A.; Winters, M. A.; Eisen, R.; Knight, T. H.; Asmuth, D. M.; Holodniy, M. | N<10
23532713 | Radiation therapy for Benign Lymphoepithelial Cysts of parotid glands in HIV patients | Laryngoscope | Mourad, W. F.; Hu, K. S.; Shourbaji, R. A.; Lin, W.; Harrison, L. B. | N<10
18269597 | Radiotherapy of classic and human immunodeficiency virus-related Kaposi's sarcoma: results in 1482 lesions | J Eur Acad Dermatol Venereol | Caccialanza, M.; Marca, S.; Piccinno, R.; Eulisse, G. | N<10
16549833 | Randomized phase II trial of matrix metalloproteinase inhibitor COL-3 in AIDS-related Kaposi's sarcoma: an AIDS Malignancy Consortium Study | J Clin Oncol | Dezube, B. J.; Krown, S. E.; Lee, J. Y.; Bauer, K. S.; Aboulafia, D. M. | N<10
24352352 | Randomized trial of central nervous system-targeted antiretrovirals for HIV-associated neurocognitive disorder | Clin Infect Dis | Ellis, R. J.; Letendre, S.; Vaida, F.; Haubrich, R.; Heaton, R. K.; Sacktor, N.; Clifford, D. B.; Best, B. M.; May, S.; Umlauf, A.; Cherner, M.; Sanders, C.; Ballard, C.; Simpson, D. M.; Jay, C.; McCutchan, J. A. | N<10
20564162 | Randomized trial of paclitaxel versus pegylated liposomal doxorubicin for advanced human immunodeficiency virus-associated Kaposi sarcoma: evidence of symptom palliation from chemotherapy | Cancer | Cianfrocca, M.; Lee, S.; Von Roenn, J.; Tulpule, A.; Dezube, B. J.; Aboulafia, D. M.; Ambinder, R. F.; Lee, J. Y.; Krown, S. E.; Sparano, J. A. | N<10
17493483 | Relation of subepicardial adipose tissue to carotid intima-media thickness in patients with human immunodeficiency virus | Am J Cardiol | Iacobellis, G.; Pellicelli, A. M.; Sharma, A. M.; Grisorio, B.; Barbarini, G.; Barbaro, G. | N<10
22223822 | Rituximab decreases the risk of lymphoma in patients with HIV-associated multicentric Castleman disease | Blood | Gerard, L.; Michot, J. M.; Burcheri, S.; Fieschi, C.; Longuet, P.; Delcey, V.; Meignin, V.; Agbalika, F.; Chevret, S.; Oksenhendler, E.; Galicier, L. | N<10
25784439 | Role of intestinal myofibroblasts in HIV-associated intestinal collagen deposition and immune reconstitution following combination antiretroviral therapy | Aids | Asmuth, D. M. | N<10
23032420 | Safety and efficacy of topical cidofovir to treat high-grade perianal and vulvar intraepithelial neoplasia in HIV-positive men and women | Aids | Stier, E. A.; Goldstone, S. E.; Einstein, M. H.; Jay, N.; Berry, J. M.; Wilkin, T.; Lee, J. Y.; Darragh, T. M.; Da Costa, M.; Panther, L.; Aboulafia, D.; Palefsky, J. M. | N<10
23075918 | Safety, tolerability, and pharmacokinetics of the HIV integrase inhibitor dolutegravir given twice daily with rifampin or once daily with rifabutin: results of a phase 1 study among healthy subjects | J Acquir Immune Defic Syndr | Dooley, K. E.; Sayre, P.; Borland, J.; Purdy, E.; Chen, S.; Song, I.; Peppercorn, A.; Everts, S.; Piscitelli, S.; Flexner, C. | N<10
22022854 | Seeking information about HIV/AIDS: a qualitative study of health literacy among people living with HIV/AIDS in a low prevalence context | AIDS Care | Zukoski, A. P.; Thorburn, S.; Stroud, J. | N<10
19890073 | Selegiline and oxidative stress in HIV-associated cognitive impairment | Neurology | Schifitto, G.; Yiannoutsos, C. T.; Ernst, T.; Navia, B. A.; Nath, A.; Sacktor, N.; Anderson, C.; Marra, C. M.; Clifford, D. B. | N<10
19387421 | Sexually transmitted infections among patients with acute HIV in North Carolina | Sex Transm Dis | McCoy, S. I.; Eron, J. J.; Kuruc, J. D.; Strauss, R. P.; Macdonald, P. D.; Fiscus, S. A.; Barnhart, J.; Pilcher, C. D.; Leone, P. A.; Miller, W. C. | N<10
24988179 | Short communication: effects of omega-3 fatty acids on triglycerides and high-density lipoprotein subprofiles in HIV-infected persons with hypertriglyceridemia | AIDS Res Hum Retroviruses | Paranandi, A.; Asztalos, B. F.; Mangili, A.; Kuvin, J.; Gerrior, J.; Sheehan, H.; Skinner, S. C.; Tang, A. M.; Wanke, C. A. | N<10
24946792 | Short communication: serum-based assay accurately detects single nucleotide polymorphisms of IL28B and SOCS3 in HIV/hepatitis C virus-coinfected subjects | AIDS Res Hum Retroviruses | Shaffer, A.; Hubbard, J. J.; Townsend, K.; Kottilil, S.; Polis, M. A.; Masur, H.; Kohli, A. | N<10
24707838 | Short communication: spectrum of non-Hodgkin lymphoma in an urban Ryan White-funded clinic in the established antiretroviral era | AIDS Res Hum Retroviruses | Silverton, A.; Gunthel, C.; Adamski, M.; Mosunjac, M.; Nguyen, M. L. | N<10
22648891 | Short-course intravenous aciclovir treatment for cutaneous herpes zoster in patients with HIV infection | Int J STD AIDS | Noonan, L.; Gunson, T.; Ellis-Pegler, R.; Thomas, M.; Briggs, S. | N<10
20216298 | Short-term effects of extended-release niacin on endothelial function in HIV-infected patients on stable antiretroviral therapy | Aids | Chow, D. C.; Stein, J. H.; Seto, T. B.; Mitchell, C.; Sriratanaviriyakul, N.; Grandinetti, A.; Gerschenson, M.; Shiramizu, B.; Souza, S.; Shikuma, C. | N<10
16122775 | Simian virus 40 tumor antigen expression and immunophenotypic profile of AIDS-related non-Hodgkin's lymphoma | Virology | Vilchez, R. A.; Lopez-Terrada, D.; Middleton, J. R.; Finch, C. J.; Killen, D. E.; Zanwar, P.; Jorgensen, J. L.; Butel, J. S. | N<10
105985338. Language: | Supporting Positive Living and Sexual Health (SPLASH): A Clinician and Behavioral Counselor Risk-Reduction Intervention in a University-Based HIV Clinic | AIDS & Behavior | ZÃºÃ±iga, M.; Baldwin, H.; Uhler, D.; Brennan, J.; Olshefsky, A.; Oliver, E.; Mathews, W. | N<10
104268692. Language: | Taking a Half Day at a Time:' Patient Perspectives and the HIV Engagement in Care Continuum | AIDS Patient Care & STDs | Christopoulos, Katerina A.; Massey, Amina D.; Lopez, Andrea M.; Geng, Elvin H.; Johnson, Mallory O.; Pilcher, Christopher D.; Fielding, Hegla; Dawson-Rose, Carol | N<10
22103666 | The effects of a harm reduction housing program on the viral loads of homeless individuals living with HIV/AIDS | AIDS Care | Hawk, M.; Davis, D. | N<10
19012081 | The effects of low literacy and cognitive impairment on medication adherence in HIV-positive injecting drug users | AIDS Care | Waldrop-Valverde, D.; Jones, D. L.; Weiss, S.; Kumar, M.; Metsch, L. | N<10
19397460 | Therapeutic drug monitoring of antimycobacterial drugs in patients with both tuberculosis and advanced human immunodeficiency virus infection | Pharmacotherapy | Holland, D. P.; Hamilton, C. D.; Weintrob, A. C.; Engemann, J. J.; Fortenberry, E. R.; Peloquin, C. A.; Stout, J. E. | N<10
19898214 | Therapeutic response to peg-IFN-alpha-2b and ribavirin in HIV/HCV co-infected African-American and Caucasian patients as a function of HCV viral kinetics and interferon pharmacodynamics | Aids | Rozenberg, L.; Haagmans, B. L.; Neumann, A. U.; Chen, G.; McLaughlin, M.; Levy-Drummer, R. S.; Masur, H.; Dewar, R. L.; Ferenci, P.; Silva, M.; Viola, M. S.; Polis, M. A.; Kottilil, S. | N<10
25387314 | Therapy with boceprevir or telaprevir in HIV/hepatitis C virus co-infected patients to treat recurrence of hepatitis C virus infection after liver transplantation | Aids | Antonini, T. M.; Furlan, V.; Teicher, E.; Haim-Boukobza, S.; Sebagh, M.; Coilly, A.; Bonhomme-Faivre, L.; Roque-Afonso, A. M.; Vittecoq, D.; Samuel, D.; Taburet, A. M.; Duclos-Vallee, J. C. | N<10
21622971 | Treatment for hepatitis C virus with pegylated interferon-alpha plus ribavirin induces anti-atherogenic effects on cardiovascular risk biomarkers in HIV-infected and -uninfected patients | J Antimicrob Chemother | Masia, M.; Robledano, C.; Lopez, N.; Escolano, C.; Gutierrez, F. | N<10
15824988 | Treatment of multidrug-resistant tuberculosis in San Francisco: an outpatient-based approach | Clin Infect Dis | Burgos, M.; Gonzalez, L. C.; Paz, E. A.; Gournis, E.; Kawamura, L. M.; Schecter, G.; Hopewell, P. C.; Daley, C. L. | N<10
19478647 | Treatment of spondylodiscitis in human immunodeficiency virus-infected patients: a comparison of conservative and operative therapy | Spine (Phila Pa 1976) | Sobottke, R.; Zarghooni, K.; Krengel, M.; Delank, S.; Seifert, H.; Fatkenheuer, G.; Ernestus, I.; Kallicke, T.; Frangen, T.; Arasteh, K.; Oette, M.; Eysel, P. | N<10
19323617 | Trimethoprim-sulfamethoxazole exposure alters ex vivo function of B lymphocytes isolated from human immunodeficiency virus-infected patients receiving Zidovudine | Pharmacotherapy | Venugopalan, V.; Thornton, A. C.; Steinke, D. T.; Rapp, R. P.; Romanelli, F.; Feola, D. J. | N<10
18163214 | Tripling of methamphetamine/amphetamine use among homeless and marginally housed persons, 1996-2003 | J Urban Health | Das-Douglas, M.; Colfax, G.; Moss, A. R.; Bangsberg, D. R.; Hahn, J. A. | N<10
21593619 | Twice-weekly pegylated interferon-alpha-2a and ribavirin results in superior viral kinetics in HIV/hepatitis C virus co-infected patients compared to standard therapy | Aids | Murphy, A. A.; Herrmann, E.; Osinusi, A. O.; Wu, L.; Sachau, W.; Lempicki, R. A.; Yang, J.; Chung, T. L.; Wood, B. J.; Haagmans, B. L.; Kottilil, S.; Polis, M. A. | N<10
103796328. Language: | Understanding Concerns About Treatment-as-Prevention Among People with HIV who are not Using Antiretroviral Therapy | AIDS & Behavior | Newman, C.; Wit, J.; Persson, A.; Holt, M.; Slavin, S.; Kidd, M.; Post, J.; Wright, E.; Mao, L. | N<10
24708752 | Understanding HIV care delays in the US South and the role of the social-level in HIV care engagement/retention: a qualitative study | Int J Equity Health | Sprague, C.; Simon, S. E. | N<10
22612447 | Understanding the behavioral determinants of retention in HIV care: a qualitative evaluation of a situated information, motivation, behavioral skills model of care initiation and maintenance | AIDS Patient Care STDS | Smith, L. R.; Fisher, J. D.; Cunningham, C. O.; Amico, K. R. | N<10
21986870 | Urban farming: a non-traditional intervention for HIV-related distress | AIDS Behav | Shacham, E.; Donovan, M. F.; Connolly, S.; Mayrose, A.; Scheuermann, M.; Overton, E. T. | N<10
16829362 | Becoming adherent: experiences of persons living with HIV/AIDS | J Assoc Nurses AIDS Care | Gray, J. | N<10
23663016 | Clients' Perspectives of the Relationship of Vulnerability and Resilience in the Context of HIV Infection | Issues in Mental Health Nursing | De Santis, Joseph P. | N<10
18056946 | Effects of pharmacists' interventions on patient outcomes in an HIV primary care clinic | Am J Health Syst Pharm | March, K.; Mak, M.; Louie, S. G. | N<10
104968744. Language: | Hepatitis C virus treatment rates and outcomes in HIV/hepatitis C virus co-infected individuals at an urban HIV clinic | European Journal of Gastroenterology & Hepatology | Murray, Melanie C. M.; Barrios, Rolando; Zhang, Wendy; Hull, Mark; Montessori, Valentina; Hogg, Robert S.; Montaner, Julio S. G. | N<10
23339916 | Interferon gamma in patients with HIV/AIDS and suspicion or latent tuberculosis infection | Asian Pac J Trop Med | Garcia-Elorriaga, G.; Martinez-Velazquez, M.; Gaona-Flores, V.; del Rey-Pineda, G.; Gonzalez-Bonilla, C. | N<10
21692572 | Living in silence: a grounded theory study of vulnerability in the context of HIV infection | Issues Ment Health Nurs | De Santis, J. P.; Barroso, S. | N<10
2010-01305-001 | Precipitating circumstances of suicide among women of reproductive age in 16 U.S. states, 2003â€“2007 | Journal of Women's Health | Ortega, LaVonne A. G.; Karch, Debra | N<10
17064995 | Presentation and outcomes of systemic non-Hodgkin's lymphoma: a comparison between patients with acquired immunodeficiency syndrome (AIDS) treated with highly active antiretroviral therapy and patients without AIDS | Leuk Lymphoma | Diamond, C.; Taylor, T. H.; Im, T.; Anton-Culver, H. | N<10
18661394 | Treatment patterns and prognosis in patients with human immunodeficiency virus and primary central system lymphoma | Leuk Lymphoma | Kreisl, T. N.; Panageas, K. S.; Elkin, E. B.; Deangelis, L. M.; Abrey, L. E. | N<10
21732897 | Acceptance-based behavior therapy to promote HIV medication adherence | AIDS Care | Moitra, E.; Herbert, J. D.; Forman, E. M. | N<10
26102447 | Cost-Effectiveness of Collaborative Care for Depression in HIV Clinics | J Acquir Immune Defic Syndr | Painter, J. T. | N<10
25504449 | Individualized texting for adherence building (iTAB): improving antiretroviral dose timing among HIV-infected persons with co-occurring bipolar disorder | AIDS Behav | Moore, D. J. and Poquette, A. and Casaletto, K. B. | N<10
21711215 | Modified therapeutic community aftercare for clients triply diagnosed with HIV/AIDS and co-occurring mental and substance use disorders | AIDS Care | Sacks, S.; McKendrick, K.; Vazan, P.; Sacks, J. Y.; Cleland, C. M. | N<10
25529057 | Technology use in linking criminal justice reentrants to HIV care in the community: a qualitative formative research study | J Health Commun | Peterson, J.; Cota, M.; Gray, H.; Bazerman, L.; Kuo, I.; Kurth, A.; Beckwith, C. | N<10
25480096 | The impact of recent cocaine use on plasma levels of methadone and buprenorphine in patients with and without HIV-infection | J Subst Abuse Treat | Tetrault, J. M. | N<10
24817835 | Access to HIV Care and Support Services for African American Transwomen Living with HIV | International Journal of Transgenderism | Wilson, Erin C.; Arayasirikul, Sean; Johnson, Kelly | N<10
105575973. Language: | Distinct mechanisms for mitochondrial DNA loss in T and B lymphocytes from HIV-infected patients exposed to nucleoside reverse-transcriptase inhibitors and those naive to antiretroviral treatment | Journal of Infectious Diseases | Maagaard, A.; Holberg-Petersen, M.; LÃ¸vgÃ¥rden, G.; Holm, M.; Pettersen, F. O.; Kvale, D. | N<10
16537287 | Interpersonal issues surrounding HIV counseling and testing, and the phenomenon of ‘testing by proxy’ | J Health Commun | Morrill, A. C.; Noland, C. | N<10
20130244 | The role of tumor histogenesis, FDG-PET, and short-course EPOCH with dose-dense rituximab (SC-EPOCH-RR) in HIV-associated diffuse large B-cell lymphoma | Blood | Dunleavy, K.; Little, R. F.; Pittaluga, S.; Grant, N.; Wayne, A. S.; Carrasquillo, J. A.; Steinberg, S. M.; Yarchoan, R.; Jaffe, E. S.; Wilson, W. H. | N<10
24840761 | Clinician adherence to recommendations for screening of adolescents for sexual activity and sexually transmitted infection/human immunodeficiency virus | J Pediatr | Goyal, M. K.; Witt, R.; Hayes, K. L.; Zaoutis, T. E.; Gerber, J. S. | Not enrolling population of interest
23429891 | Increased risk of sudden sensorineural hearing loss in patients with human immunodeficiency virus aged 18 to 35 years: a population-based cohort study | JAMA Otolaryngol Head Neck Surg | Lin, C.; Lin, S. W.; Weng, S. F.; Lin, Y. S. | Not enrolling population of interest
18723381 | Hepatitis B vaccine: a seven-year study of adherence to the immunization guidelines and efficacy in HIV-1-positive adults | Int J Infect Dis | Bailey, C. L.; Smith, V.; Sands, M. | Not enrolling population of interest
18039996 | A framework for tailoring clinical guidelines to comorbidity at the point of care | Arch Intern Med | Braithwaite, R. S.; Concato, J.; Chang, C. C.; Roberts, M. S.; Justice, A. C. | Not enrolling population of interest
16327098 | Injection drug use among homeless adults in the Southeast with severe mental illness | J Health Care Poor Underserved | Linn, J. G.; Brown, M.; Kendrick, L. | Not enrolling population of interest
23568228 | A randomized controlled trial examining the efficacy of motivational counseling with observed therapy for antiretroviral therapy adherence | AIDS Behav | Goggin, K.; Gerkovich, M. M.; Williams, K. B.; Banderas, J. W.; Catley, D.; Berkley-Patton, J.; Wagner, G. J.; Stanford, J.; Neville, S.; Kumar, V. K.; Bamberger, D. M.; Clough, L. A. | Not enrolling population of interest
106463271. Language: | The Caribbean/West Indies cultural competency program for Florida nurses: implications for HIV/AIDS prevention and treatment | Journal of Multicultural Nursing & Health (JMCNH) | Jones, S. G. | Not enrolling population of interest
21947780 | Interest in, concerns about, and preferences for potential video-group delivery of an effective behavioral intervention among women living with HIV | AIDS Behav | Marhefka, S. L.; Fuhrmann, H. J.; Gilliam, P.; Lopez, B.; Baldwin, J. | Not enrolling population of interest
21197926 | The use of the Zung Self-Rating Depression Scale to assist in the case management of patients living with HIV/AIDS | Care Manag J | Lombardi, D.; Mizuno, L. T.; Thornberry, A. | Not enrolling population of interest
2010-21826-032 | Effects of stress on health in HIV/AIDS | The handbook of stress science: Biology, psychology, and health. | Perez, Giselle K.; Cruess, Dean G.; Kalichman, Seth C. | Not enrolling population of interest
103936553. Language: | Substance Abuse Treatment in Persons withÂ HIV/AIDS: Challenges in Managing Triple Diagnosis | Behavioral Medicine | Durvasula, Ramani; Miller, Theodore R. | Not enrolling population of interest
22227844 | A cost-effectiveness analysis of anal cancer screening in HIV-positive women | J Low Genit Tract Dis | Lazenby, G. B.; Unal, E. R.; Andrews, A. L.; Simpson, K. | Not enrolling population of interest
19561518 | Improving outcomes in state AIDS drug assistance programs | J Acquir Immune Defic Syndr | Linas, B. P.; Losina, E.; Rockwell, A.; Walensky, R. P.; Cranston, K.; Freedberg, K. A. | Not enrolling population of interest
21182348 | US cost effectiveness of darunavir/ritonavir 600/100 mg bid in treatment-experienced, HIV-infected adults with evidence of protease inhibitor resistance included in the TITAN Trial | Pharmacoeconomics | Brogan, A.; Mauskopf, J.; Talbird, S. E.; Smets, E. | Not enrolling population of interest
25393748 | Testing for human immunodeficiency virus among cancer survivors under age 65 in the United States | Prev Chronic Dis | Li, J.; Thompson, T. D.; Tai, E.; Zhao, G.; Oster, A. M. | Not enrolling population of interest
21771748 | Pain, sleep disturbance and survival in hemodialysis patients | Nephrol Dial Transplant | Harris, T. J.; Nazir, R.; Khetpal, P.; Peterson, R. A.; Chava, P.; Patel, S. S.; Kimmel, P. L. | Not enrolling population of interest
20639562 | Routine opt-out rapid HIV screening and detection of HIV infection in emergency department patients | Jama | Haukoos, J. S.; Hopkins, E.; Conroy, A. A.; Silverman, M.; Byyny, R. L.; Eisert, S.; Thrun, M. W.; Wilson, M. L.; Hutchinson, A. B.; Forsyth, J.; Johnson, S. C.; Heffelfinger, J. D. | Not enrolling population of interest
16963388 | Promoting female condom use to heterosexual couples: findings from a randomized clinical trial | Perspect Sex Reprod Health | Witte, S. S.; El-Bassel, N.; Gilbert, L.; Wu, E.; Chang, M.; Hill, J. | Not enrolling population of interest
22623771 | B-lymphocyte dysfunction in chronic HIV-1 infection does not prevent cross-clade neutralization breadth | J Virol | Boliar, S.; Murphy, M. K.; Tran, T. C.; Carnathan, D. G.; Armstrong, W. S.; Silvestri, G.; Derdeyn, C. A. | Not enrolling population of interest
20950406 | HIV and HCV health beliefs in an inner-city community | J Viral Hepat | Krauskopf, K.; McGinn, T. G.; Federman, A. D.; Halm, E. A.; Leventhal, H.; McGinn, L. K.; Gardenier, D.; Oster, A.; Kronish, I. M. | Not enrolling population of interest
17855466 | HIV risk reduction in a nurse case-managed TB and HIV intervention among homeless adults | J Health Psychol | Schumann, A.; Nyamathi, A.; Stein, J. A. | Not enrolling population of interest
24558098 | Outcomes of a behavioral intervention to reduce HIV risk among drug-involved female sex workers | AIDS Behav | Surratt, H. L.; O'Grady, C.; Kurtz, S. P.; Levi-Minzi, M. A.; Chen, M. | Not enrolling population of interest
15890044 | Supportive-affective group experience for persons with life-threatening illness: reducing spiritual, psychological, and death-related distress in dying patients | J Palliat Med | Miller, D. K.; Chibnall, J. T.; Videen, S. D.; Duckro, P. N. | Not enrolling population of interest
24138486 | The impact of anticipated HIV stigma on delays in HIV testing behaviors: findings from a community-based sample of men who have sex with men and transgender women in New York City | AIDS Patient Care STDS | Golub, S. A.; Gamarel, K. E. | Not enrolling population of interest
104192425. Language: | A Comparison of Modified Directly Observed Therapy to Standard Care for Chronic Hepatitis C | Journal of Community Health | Cioe, Patricia; Stein, Michael; Promrat, Kittichai; Friedmann, Peter | Not enrolling population of interest
19046120 | Impact of service delivery model on health care access among HIV-positive women in New York City | AIDS Patient Care STDS | Pillai, N. V.; Kupprat, S. A.; Halkitis, P. N. | Not enrolling population of interest
15765367 | A peer-based substance abuse intervention for HIV+ rural women: a pilot study | Arch Psychiatr Nurs | Boyd, M. R.; Moneyham, L.; Murdaugh, C.; Phillips, K. D.; Tavakoli, A.; Jackwon, K.; Jackson, N.; Vyavaharkar, M. | Not enrolling population of interest
22051219 | Social network characteristics and heavy episodic drinking among women at risk for HIV/sexually transmitted infections | J Stud Alcohol Drugs | Davey-Rothwell, M. A.; Chander, G.; Hester, L.; Latkin, C. A. | Not enrolling population of interest
16488825 | Self-esteem, emotional distress and sexual behavior among adolescent females: inter-relationships and temporal effects | J Adolesc Health | Ethier, K. A.; Kershaw, T. S.; Lewis, J. B.; Milan, S.; Niccolai, L. M.; Ickovics, J. R. | Not enrolling population of interest
19440109 | Psychiatric diagnosis and antiretroviral adherence among adolescent Medicaid beneficiaries diagnosed with human immunodeficiency virus/acquired immunodeficiency syndrome | J Nerv Ment Dis | Walkup, J.; Akincigil, A.; Bilder, S.; Rosato, N. S.; Crystal, S. | Not enrolling population of interest
21937041 | Comparison of a theory-based (AIDS Risk Reduction Model) cognitive behavioral intervention versus enhanced counseling for abused ethnic minority adolescent women on infection with sexually transmitted infection: results of a randomized controlled trial | Int J Nurs Stud | Champion, J. D.; Collins, J. L. | Not enrolling population of interest
2012-99080-598 | Exploring secondary abstinence among African-American females at risk for HIV/STIs: A mixed-methods investigation | | Bradley, Erin Lyndsay Paige | Not enrolling population of interest
25372391 | HIV Treatment Adherence Measurement and Reporting Concordance in Youth with Perinatally Acquired HIV Infection and Their Caregivers | AIDS Patient Care & STDs | Evans, Shenell D.; Mellins, Claude Ann; Leu, Cheng-Shiun; Warne, Patricia; Elkington, Katherine S.; Dolezal, Curtis; Santamaria, E. Karina; Wiznia, Andrew; Bamji, Mahrukh; Jurgrau-Voulgari, Andrea S.; Abrams, Elaine J. | Not enrolling population of interest
24391801 | Outcomes among HIV-1 infected individuals first starting antiretroviral therapy with concurrent active TB or other AIDS-defining disease | PLoS One | Perisse, A. R.; Smeaton, L.; Chen, Y.; La Rosa, A.; Walawander, A.; Nair, A.; Grinsztejn, B.; Santos, B.; Kanyama, C.; Hakim, J.; Nyirenda, M.; Kumarasamy, N.; Lalloo, U. G.; Flanigan, T.; Campbell, T. B.; Hughes, M. D. | Not enrolling population of interest
15812609 | Long-term effects of an HIV/STI sexual risk reduction intervention for heterosexual couples | AIDS Behav | El-Bassel, N.; Witte, S. S.; Gilbert, L.; Wu, E.; Chang, M.; Hill, J.; Steinglass, P. | Not enrolling population of interest
16166868 | Availability of medical care services in drug treatment clinics associated with lower repeated emergency department use | Med Care | Laine, C.; Lin, Y. T.; Hauck, W. W.; Turner, B. J. | Not enrolling population of interest
19417194 | Effect of a housing and case management program on emergency department visits and hospitalizations among chronically ill homeless adults: a randomized trial | Jama | Sadowski, L. S.; Kee, R. A.; VanderWeele, T. J.; Buchanan, D. | Not enrolling population of interest
24376623 | Association between Mycobacterium tuberculosis complex phylogenetic lineage and acquired drug resistance | PLoS One | Yuen, C. M.; Kurbatova, E. V.; Click, E. S.; Cavanaugh, J. S.; Cegielski, J. P. | Not enrolling population of interest
20020194 | HIV risks and seroprevalence among Mexican American injection drug users in California | AIDS Behav | Martinez, A. N.; Bluthenthal, R. N.; Flynn, N. M.; Anderson, R. L.; Kral, A. H. | Not enrolling population of interest
23872994 | Results of a pilot test of a brief computer-assisted tailored HIV prevention intervention for use with a range of demographic and risk groups | AIDS Behav | Zule, W. A.; Bobashev, G. V.; Reif, S. M.; Poulton, W.; Coomes, C. M.; Wechsberg, W. M. | Not enrolling population of interest
109831857. Language: | A Randomized Trial to Evaluate the Efficacy of a Web-Based HIV Behavioral Intervention for High-Risk African American Women | AIDS & Behavior | Billings, Douglas; Leaf, Samantha; Spencer, Joy; Crenshaw, Terrlynn; Brockington, Sheila; Dalal, Reeshad | Not enrolling population of interest
15671808 | Are HIV/AIDS conspiracy beliefs a barrier to HIV prevention among African Americans? | J Acquir Immune Defic Syndr | Bogart, L. M.; Thorburn, S. | Not enrolling population of interest
22166909 | Are older patients comfortable discussing sexual health with nurses? | Nurs Res | Farrell, J.; Belza, B. | Not enrolling population of interest
20626196 | Economically motivated relationships and transactional sex among unmarried African American and white women: results from a U.S. national telephone survey | Public Health Rep | Dunkle, K. L.; Wingood, G. M.; Camp, C. M.; DiClemente, R. J. | Not enrolling population of interest
22021297 | Efficacy of a health educator-delivered HIV prevention intervention for Latina women: a randomized controlled trial | Am J Public Health | Wingood, G. M.; DiClemente, R. J.; Villamizar, K.; Er, D. L.; DeVarona, M.; Taveras, J.; Painter, T. M.; Lang, D. L.; Hardin, J. W.; Ullah, E.; Stallworth, J.; Purcell, D. W.; Jean, R. | Not enrolling population of interest
18684571 | Ethnic differences in HIV risk behaviors among methadone-maintained women receiving contingency management for cocaine use disorders | Drug Alcohol Depend | Barry, D.; Weinstock, J.; Petry, N. M. | Not enrolling population of interest
21573724 | Evaluation of an HIV prevention intervention for African Americans and Hispanics: findings from the VOICES/VOCES Community-based Organization Behavioral Outcomes Project | AIDS Behav | Fisher, H. H.; Patel-Larson, A.; Green, K.; Shapatava, E.; Uhl, G.; Kalayil, E. J.; Moore, A.; Williams, W.; Chen, B. | Not enrolling population of interest
24059881 | Influences of stigma and HIV transmission knowledge on member support for faith-placed HIV initiatives in Chinese immigrant Buddhist and protestant religious institutions in New York City | AIDS Educ Prev | Kang, E.; Delzell, D. A.; Chin, J. J.; Behar, E.; Li, M. Y. | Not enrolling population of interest
21371849 | Injection drug users' experience with and attitudes toward methadone clinics in Denver, CO | J Subst Abuse Treat | Al-Tayyib, A. A.; Koester, S. | Not enrolling population of interest
23607674 | Relationship between menopause symptoms and HIV risk among midlife women in methadone treatment: a pilot study | Subst Use Misuse | Tuchman, E.; Pennington, L. E.; Kull, R. M.; Daneshyar, S. | Not enrolling population of interest
19229682 | The effect of sympathy on discriminatory attitudes toward persons living with HIV/AIDS in Puerto Rico: a hierarchical analysis of women living in public housing | AIDS Care | Norman, L. R.; Abreu, S.; Candelaria, E.; Sala, A. | Not enrolling population of interest
2008-99130-473 | Correlates of Voluntary HIV Testing and Counseling among middle aged and older Latinas | | Craig, Shelley L. | Not enrolling population of interest
106540073. Language: | Field action report. Get connected: an HIV prevention case management program for men and women leaving California prisons | American Journal of Public Health | Myers, J.; Zack, B.; Kramer, K.; Gardner, M.; Rucobo, G.; Costa-Taylor, S. | Not enrolling population of interest
106414872. Language: | Primary care and health among women released from New York City jails | Journal of Health Care for the Poor & Underserved | Lee, J.; Vlahov, D.; Freudenberg, N. | Not enrolling population of interest
105131060. Language: | The relationship between program implementation and evaluation on the TCE/HIV projects | Journal of Evidence-Based Social Work | Kinnevy, S. C.; Sununu, T. J. | Not enrolling population of interest
16036235 | Prediction of adherence to antiretroviral therapy: a one-year longitudinal study | AIDS Care | Godin, G.; Cote, J.; Naccache, H.; Lambert, L. D.; Trottier, S. | Not enrolling population of interest
22189509 | Primary liver cancer is more aggressive in HIV-HCV coinfection than in HCV infection. A prospective study (ANRS CO13 Hepavih and CO12 Cirvir) | Clin Res Hepatol Gastroenterol | Bourcier, V.; Winnock, M.; Ait Ahmed, M.; Sogni, P.; Pambrun, E.; Poizot-Martin, I.; Chaffaut, C.; Chevret, S.; Trinchet, J. C.; Salmon, D. | Not enrolling population of interest
15578686 | Weekly docetaxel is safe and effective in the treatment of advanced-stage acquired immunodeficiency syndrome-related Kaposi sarcoma | Cancer | Lim, S. T.; Tupule, A.; Espina, B. M.; Levine, A. M. | Not enrolling population of interest
2005-06361-003 | Improving the Access and Quality of Public Health Services for Bisexuals | Journal of Bisexuality | Dobinson, Cheryl; MacDonnell, Judy; Hampson, Elaine; Clipsham, Jean; Chow, Kathy | Not enrolling population of interest
19116782 | HIV services utilization in Los Angeles County, California | AIDS Behav | Fisher, D. G.; Wishart, D.; Reynolds, G. L.; Edwards, J. W.; Kochems, L. M.; Janson, M. A. | Not enrolling population of interest
22628662 | Sickle cell disease is associated with decreased HIV but higher HBV and HCV comorbidities in U.S. hospital discharge records: a cross-sectional study | Sex Transm Infect | Nouraie, M.; Nekhai, S.; Gordeuk, V. R. | Not enrolling population of interest
25162598 | Food insecurity with hunger is associated with obesity among HIV-infected and at risk women in Bronx, NY | PLoS One | Sirotin, N.; Hoover, D. R.; Shi, Q.; Anastos, K.; Weiser, S. D. | Not enrolling population of interest
16107987 | Mortality in an urban cohort of HIV-infected and at-risk drug users in the era of highly active antiretroviral therapy | Clin Infect Dis | Kohli, R.; Lo, Y.; Howard, A. A.; Buono, D.; Floris-Moore, M.; Klein, R. S.; Schoenbaum, E. E. | Not enrolling population of interest
16134565 | Health department collaboration with emergency departments as a model for public health programs among at-risk populations | Public Health Rep | Lyons, M. S.; Lindsell, C. J.; Ledyard, H. K.; Frame, P. T.; Trott, A. T. | Not enrolling population of interest
2015-99231-045 | Mental health service utilization among people with mental illness: An examination of predictors and the influence of substance abuse and hiv | | Chang, Man-Chun | Not enrolling population of interest
17298935 | Community-level HIV prevention for persons with severe mental illness living in supportive housing programs: a pilot intervention study | J Prev Interv Community | Sikkema, K. J.; Meade, C. S.; Doughty-Berry, J. D.; Zimmerman, S. O.; Kloos, B.; Snow, D. L. | Not enrolling population of interest
105566829. Language: | Implications for HIV/AIDS research and education among ethnic minority older adults | Journal of HIV/AIDS & Social Services | Altschuler, I.; Katz, A. D.; Tynan, M. A. | Not enrolling population of interest
20178023 | Case management outcomes for women who use crack | J Evid Based Soc Work | Corsi, K. F.; Rinehart, D. J.; Kwiatkowski, C. F.; Booth, R. E. | Not enrolling population of interest
21517659 | Race and emotion in computer-based HIV prevention videos for emergency department patients | AIDS Educ Prev | Aronson, I. D.; Bania, T. C. | Not enrolling population of interest
23811030 | A multidisciplinary support programme increases the efficiency of pegylated interferon alfa-2a and ribavirin in hepatitis C | J Hepatol | Carrion, J. A.; Gonzalez-Colominas, E.; Garcia-Retortillo, M.; Canete, N.; Cirera, I.; Coll, S.; Gimenez, M. D.; Marquez, C.; Martin-Escudero, V.; Castellvi, P.; Navines, R.; Castano, J. R.; Galeras, J. A.; Salas, E.; Bory, F.; Martin-Santos, R.; Sola, R. | Not enrolling population of interest
25616838 | A Randomized Trial to Evaluate the Efficacy of a Web-Based HIV Behavioral Intervention for High-Risk African American Women | AIDS Behav | Billings, D. W. | Not enrolling population of interest
24242259 | Assessment of HIV-related stigma in a US faith-based HIV education and testing intervention | J Int AIDS Soc | Berkley-Patton, J. Y.; Moore, E.; Berman, M.; Simon, S. D.; Thompson, C. B.; Schleicher, T.; Hawes, S. M. | Not enrolling population of interest
20053235 | Effectiveness of increasing emergency department patients' self-perceived risk for being human immunodeficiency virus (HIV) infected through audio computer self-interview-based feedback about reported HIV risk behaviors | Acad Emerg Med | Merchant, R. C.; Clark, M. A.; Langan, T. J. th; Seage, G. R., 3rd; Mayer, K. H.; DeGruttola, V. G. | Not enrolling population of interest
25433653 | Evaluating a Brief, Video-Based Sexual Risk Reduction Intervention and Assessment Reactivity with STI Clinic Patients: Results from a Randomized Controlled Trial | AIDS Behav | Carey, M. P. and Senn, T. E. and Walsh, J. L. | Not enrolling population of interest
24059880 | Housing stability, residential transience, and HIV testing among low-income urban African Americans | AIDS Educ Prev | Grieb, S. M.; Davey-Rothwell, M.; Latkin, C. A. | Not enrolling population of interest
104229174. Language: | Housing Stability, Residential Transience, and HIV Testing Among Low-Income Urban African Americans | AIDS Education & Prevention | Grieb, Suzanne M. Dolwick; Davey-Rothwell, Melissa; Latkin, Carl A. | Not enrolling population of interest
17435492 | Human immunodeficiency virus counseling, testing, and referral of close contacts to patients with pulmonary tuberculosis: feasibility and costs | J Public Health Manag Pract | Li, J.; Marks, S. M.; Driver, C. R.; Diaz, F. A.; Castro, A. F., 3rd; de Regner, A. F.; Gibson, A. E.; Dokubo-Okereke, K.; Munsiff, S. S. | Not enrolling population of interest
15958248 | Integrating hepatitis, STD, and HIV services into a drug rehabilitation program | Am J Prev Med | Gunn, R. A.; Lee, M. A.; Callahan, D. B.; Gonzales, P.; Murray, P. J.; Margolis, H. S. | Not enrolling population of interest
22506942 | Long-term follow-up after voluntary human immunodeficiency virus/sexually transmitted infection counseling, point-of-service testing, and referral to substance abuse treatment from the emergency department | Acad Emerg Med | Bernstein, E.; Heeren, T.; Winter, M.; Ashong, D.; Bliss, C.; Madico, G.; Ayalew, B.; Bernstein, J. | Not enrolling population of interest
24059875 | Project Salud: Efficacy of a community-based HIV prevention intervention for Hispanic migrant workers in south Florida | AIDS Educ Prev | Sanchez, J.; De La Rosa, M.; Serna, C. A. | Not enrolling population of interest
17414613 | The effects of preexisting medical comorbidities on mortality and length of hospital stay in acute burn injury: evidence from a national sample of 31,338 adult patients | Ann Surg | Thombs, B. D.; Singh, V. A.; Halonen, J.; Diallo, A.; Milner, S. M. | Not enrolling population of interest
25156561 | Assessment of bone mineral density in tenofovir-treated patients with chronic hepatitis B: can the fracture risk assessment tool identify those at greatest risk? | Journal of Infectious Diseases | Gill, Upkar S.; Zissimopoulos, Alexandra; Al-Shamma, Safa; Burke, Katherine; McPhail, Mark J. W.; Barr, David A.; Kallis, Yiannis N.; Marley, Richard T. C.; Kooner, Paul; Foster, Graham R.; Kennedy, Patrick T. F. | Not enrolling population of interest
22417754 | The Functional Assessment of Patients With Pulmonary Multidrug-Resistant Tuberculosis | Respiratory Care | Godoy, Marcos D. P.; Mello, Fernanda C. Q.; Lopes, Agnaldo J.; Costa, Walter; GuimarÃ£es, Fernando S.; Pacheco, Antonio G. F.; Castanho, Ivany A.; Menezes, Sara L. S. | Not enrolling population of interest
25033136 | Mortality risks among persons reporting same-sex sexual partners: evidence from the 2008 General Social Survey-National Death Index data set | Am J Public Health | Cochran, S. D.; Mays, V. M. | Not enrolling population of interest
21491291 | Barriers to providing health services for HIV/AIDS, hepatitis C virus infection and sexually transmitted infections in substance abuse treatment programs in the United States | J Addict Dis | Bini, E. J.; Kritz, S.; Brown, L. S., Jr.; Robinson, J.; Alderson, D.; Rotrosen, J. | Not enrolling population of interest
21500025 | A retrospective study of HIV antiretroviral treatment persistence in a commercially insured population in the United States | AIDS Care | Juday, T.; Grimm, K.; Zoe-Powers, A.; Willig, J.; Kim, E. | Not enrolling population of interest
24428796 | Improving HIV/STD prevention in the care of persons living with HIV through a national training program | AIDS Patient Care STDS | Dreisbach, S.; Burnside, H.; Hsu, K.; Smock, L.; Coury-Doniger, P.; Hall, C.; Marrazzo, J.; Nagendra, G.; Rietmeijer, C.; Rompalo, A.; Thrun, M. | Not enrolling population of interest
23442030 | Providers' attitudes towards treating depression and self-reported depression treatment practices in HIV outpatient care | AIDS Patient Care STDS | Bess, K. D.; Adams, J.; Watt, M. H.; O'Donnell, J. K.; Gaynes, B. N.; Thielman, N. M.; Heine, A.; Zinski, A.; Raper, J. L.; Pence, B. W. | Not enrolling population of interest
21468659 | Results of a randomized controlled trial of a peer mentor HIV/STI prevention intervention for women over an 18 month follow-up | AIDS Behav | Davey-Rothwell, M. A.; Tobin, K.; Yang, C.; Sun, C. J.; Latkin, C. A. | Not enrolling population of interest
106128174. Language: | Training substance abuse counselors about HIV medication adherence | Journal of HIV/AIDS & Social Services | Bass, M.; Linsk, N. L.; Mitchell, C. | Not enrolling population of interest
23568309 | Multi-state models for defining degrees of chronicity related to HIV-infected patient therapy adherence | Cad Saude Publica | Oliveira Rde, V.; Shimakura, S. E.; Campos, D. P.; Victoriano, F. P.; Ribeiro, S. R.; Veloso, V. G.; Grinsztejn, B.; Carvalho, M. S. | Not enrolling population of interest
22908365 | National HIV Testing Day - June 27, 2012 | MMWR Morb Mortal Wkly Rep | | Not enrolling population of interest
24499276 | Assessing baseline religious practices and beliefs to predict adherence to highly active antiretroviral therapy among HIV-infected persons | AIDS Care | Vyas, K. J.; Limneos, J.; Qin, H.; Mathews, W. C. | Not enrolling population of interest
20656678 | Changes in liver stiffness in patients with chronic hepatitis C with and without HIV co-infection treated with pegylated interferon plus ribavirin | J Antimicrob Chemother | Macias, J.; del Valle, J.; Rivero, A.; Mira, J. A.; Camacho, A.; Merchante, N.; Perez-Camacho, I.; Neukam, K.; Rivero-Juarez, A.; Mata, R.; Torre-Cisneros, J.; Pineda, J. A. | Not enrolling population of interest
17146375 | Effects of a behavioral intervention to reduce risk of transmission among people living with HIV: the healthy living project randomized controlled study | J Acquir Immune Defic Syndr | | Not enrolling population of interest
16776451 | Public-private collaboration for multidrug-resistant tuberculosis control in New York City | Int J Tuberc Lung Dis | Munsiff, S. S.; Ahuja, S. D.; Li, J.; Driver, C. R. | Not enrolling population of interest
108132536. Language: | Adherence to and effectiveness of highly active antiretroviral treatment for HIV infection: assessing the bidirectional relationship | Medical Care | Lamiraud, K.; Moatti, J. P.; Raffi, F.; Carrieri, M. P.; Protopopescu, C.; Michelet, C.; Schneider, L.; Collin, F.; Leport, C.; Spire, B. | Not enrolling population of interest
106256986. Language: | Improved adherence with contingency management | AIDS Patient Care & STDs | Rosen, M. I.; Dieckhaus, K.; McMahon, T. J.; Valdes, B.; Petry, N. M.; Cramer, J.; Rounsaville, B. | Not enrolling population of interest
24751432 | HIV risk reduction with buprenorphine-naloxone or methadone: findings from a randomized trial | J Acquir Immune Defic Syndr | Woody, G. E.; Bruce, D.; Korthuis, P. T.; Chhatre, S.; Poole, S.; Hillhouse, M.; Jacobs, P.; Sorensen, J.; Saxon, A. J.; Metzger, D.; Ling, W. | Not enrolling population of interest
18692034 | Non-invasive markers of hepatic fibrosis in patients co-infected with HCV and HIV: comparison of the APRI and FIB-4 index | Clin Chim Acta | Trang, T.; Petersen, J. R.; Snyder, N. | Not enrolling population of interest
22263299 | Qualitative analysis of an educational intervention with HIV-discordant heterosexual Latino couples | P R Health Sci J | Perez-Jimenez, D.; Orengo-Aguayo, R. E. | Not enrolling population of interest
22708483 | Defining neurocognitive impairment in HIV: deficit scores versus clinical ratings | Clin Neuropsychol | Blackstone, K.; Moore, D. J.; Franklin, D. R.; Clifford, D. B.; Collier, A. C.; Marra, C. M.; Gelman, B. B.; McArthur, J. C.; Morgello, S.; Simpson, D. M.; Ellis, R. J.; Atkinson, J. H.; Grant, I.; Heaton, R. K. | Not enrolling population of interest
23934585 | Physical exercise is associated with less neurocognitive impairment among HIV-infected adults | J Neurovirol | Dufour, C. A.; Marquine, M. J.; Fazeli, P. L.; Henry, B. L.; Ellis, R. J.; Grant, I.; Moore, D. J. | Not enrolling population of interest
18193499 | Effects of a behavioral intervention on antiretroviral medication adherence among people living with HIV: the healthy living project randomized controlled study | J Acquir Immune Defic Syndr | Johnson, M. O.; Charlebois, E.; Morin, S. F.; Remien, R. H.; Chesney, M. A. | Not enrolling population of interest
18164145 | Behavioral drug and HIV risk reduction counseling (BDRC) with abstinence-contingent take-home buprenorphine: a pilot randomized clinical trial | Drug Alcohol Depend | Chawarski, M. C.; Mazlan, M.; Schottenfeld, R. S. | Not enrolling population of interest
21790474 | Short communication routine HIV testing in the emergency department: assessment of patient perceptions | AIDS Res Hum Retroviruses | Batey, D. S.; Hogan, V. L.; Cantor, R.; Hamlin, C. M.; Ross-Davis, K.; Nevin, C.; Zimmerman, C.; Thomas, S.; Mugavero, M. J.; Willig, J. H. | Not enrolling population of interest
104235560. Language: | Adherence to HIV Treatment and Care Among Previously Homeless Jail Detainees | AIDS & Behavior | Chen, Nadine; Meyer, Jaimie; Avery, Ann; Draine, Jeffrey; Flanigan, Timothy; Lincoln, Thomas; Spaulding, Anne; Springer, Sandra; Altice, Frederick | Not enrolling population of interest
17138466 | Treatment perceptions and attitudes of older human immunodeficiency virus-infected adults | Res Social Adm Pharm | Wutoh, A. K.; Brown, C. M.; Dutta, A. P.; Kumoji, E. K.; Clarke-Tasker, V.; Xue, Z. | Not enrolling population of interest
19142817 | The relationship between housing status and HIV risk among active drug users: a qualitative analysis | Subst Use Misuse | Dickson-Gomez, J.; Hilario, H.; Convey, M.; Corbett, A. M.; Weeks, M.; Martinez, M. | Not enrolling population of interest
23528143 | Sexual HIV/HSV-2 risk among drug users in New York City: an HIV testing and counseling intervention | Subst Use Misuse | Pantin, M.; Leonard, N. R.; Hagan, H. | Not enrolling population of interest
20740376 | Unprotected sexual behavior and HIV risk in the context of primary partnerships for transgender women | AIDS Behav | Operario, D.; Nemoto, T.; Iwamoto, M.; Moore, T. | Not enrolling population of interest
24450279 | Adaptation and implementation of HoMBReS: a community-level, evidence-based HIV behavioral intervention for heterosexual Latino men in the midwestern United States | AIDS Educ Prev | Martinez, O.; Roth, A. M.; Kelle, G.; Downs, M.; Rhodes, S. D. | Not enrolling population of interest
105525941. Language: | Adapting effective narrative-based HIV-prevention interventions to increase minorities' engagement in HIV/AIDS services | Health Communication | Berkley-Patton, J.; Goggin, K.; Liston, R.; Bradley-Ewing, A.; Neville, S. | Not enrolling population of interest
20391059 | An effective HIV risk-reduction protocol for drug-using female sex workers | J Prev Interv Community | Surratt, H. L.; Inciardi, J. A. | Not enrolling population of interest
20168013 | The impact of acculturation on utilization of HIV prevention services and access to care among an at-risk Hispanic population | J Health Care Poor Underserved | Kinsler, J. J.; Lee, S. J.; Sayles, J. N.; Newman, P. A.; Diamant, A.; Cunningham, W. | Not enrolling population of interest
23666322 | Interactions between alcohol and the antiretroviral medications ritonavir or efavirenz | J Addict Med | McCance-Katz, E. F.; Gruber, V. A.; Beatty, G.; Lum, P. J.; Rainey, P. M. | Not examining outcomes of interest
18062057 | Psychosocial predictors of medication adherence among persons living with HIV | Int J Behav Med | Gauchet, A.; Tarquinio, C.; Fischer, G. | Not examining outcomes of interest
25748483 | Optimism, well-being, and perceived stigma in individuals living with HIV | AIDS Care | Ammirati, R. J. | Not examining outcomes of interest
25331267 | Psychosocial Syndemics are Additively Associated with Worse ART Adherence in HIV-Infected Individuals | AIDS Behav | Blashill, A. J. | Not examining outcomes of interest
22337933 | Intra-individual neurocognitive variability confers risk of dependence in activities of daily living among HIV-seropositive individuals without HIV-associated neurocognitive disorders | Arch Clin Neuropsychol | Morgan, E. E.; Woods, S. P.; Grant, I. | Not examining outcomes of interest
16116306 | High rates of primary Mycobacterium avium complex and Pneumocystis jiroveci prophylaxis in the United States | Med Care | Gebo, K. A.; Fleishman, J. A.; Reilly, E. D.; Moore, R. D. | Not examining outcomes of interest
24784763 | HIV protective efficacy and correlates of tenofovir blood concentrations in a clinical trial of PrEP for HIV prevention | JAIDS Journal of Acquired Immune Deficiency Syndromes | Donnell, Deborah; Baeten, Jared M.; Bumpus, NamandjÃ© N.; Brantley, Justin; Bangsberg, David R.; Haberer, Jessica E.; Mujugira, Andrew; Mugo, Nelly; Ndase, Patrick; Hendrix, Craig; Celum, Connie | Not examining outcomes of interest
105969663. Language: | Predictors of cognitive ability in adults aging with HIV: a pilot study | Clinical Gerontologist | Vance, D. E.; Woodley, R. A.; Burrage, J. R., Jr. | Not examining outcomes of interest
18071166 | Trends in tuberculosis; human immunodeficiency virus comorbidity, United States, 1993-2004 | Archives of Internal Medicine | Albalak, R. | Not examining outcomes of interest
26068721 | Brief Report: Gonorrhea and Chlamydia Testing Increasing but Still Lagging in HIV Clinics in the United States | J Acquir Immune Defic Syndr | Berry, S. A. and Ghanem, K. G. and Mathews, W. C. | Not examining outcomes of interest
18580533 | Does HIV infection influence outcomes after trauma? | Journal of Trauma | Duane, T. M.; Sekel, S.; Wolfe, L. G.; Malhotra, A. K.; Aboutanos, M. B.; Ivatury, R. R. | Not examining outcomes of interest
16315382 | Posttraumatic stress disorder symptoms and adherence among women living with HIV | Ethn Dis | Hilerio, C. M.; Martinez, J.; Zorrilla, C. D.; Torres, R. | Not examining outcomes of interest
104515858. Language: | Sex and Race Effects on Risk for Selected Outcomes among Elderly HIV-Infected Patients | JIAPAC: Journal of the International Association of Physicians in AIDS Care | Frontini, Maria and Chotalia, Jigar and Spizale, Lauren and Onya, Wilfred and Ruiz, Marco and Clark, Rebecca A. | Not examining outcomes of interest
22008756 | Increased prevalence of advanced tuberculosis in rural low tuberculosis caseload counties in North Carolina | Int J Tuberc Lung Dis | Guderian, L. J.; Miller, W. C.; Sena, A. C.; Stout, J. E. | Not examining outcomes of interest
25234826 | Liver stiffness and aspartate aminotransferase levels predict the risk for liver fibrosis progression in hepatitis C virus/HIV-coinfected patients | HIV Med | Gonzalez, F. A. | Not examining outcomes of interest
25604495 | Soluble insulin receptor as a source of insulin resistance and cognitive impairment in HIV-seropositive women | J Neurovirol | Gerena, Y. and Menendez-Delmestre, R. and Skolasky, R. L. | Not examining outcomes of interest
18160373 | The role of spirituality in sustaining the psychological well-being of HIV-positive black women | Women Health | Braxton, N. D.; Lang, D. L.; M. Sales J; Wingood, G. M.; DiClemente, R. J. | Not examining outcomes of interest
22860997 | Health care utilization in HIV-infected patients: assessing the burden of hepatitis C virus coinfection | AIDS Patient Care STDS | Norton, B. L.; Park, L.; McGrath, L. J.; Proeschold Bell, R. J.; Muir, A. J.; Naggie, S. | Not examining outcomes of interest
19474756 | Prevalence of cervical cancer screening of HIV-infected women in the United States | J Acquir Immune Defic Syndr | Oster, A. M.; Sullivan, P. S.; Blair, J. M. | Not examining outcomes of interest
19394735 | Hepatitis C seropositivity and kidney function decline among women with HIV: data from the Women's Interagency HIV Study | Am J Kidney Dis | Tsui, J.; Vittinghoff, E.; Anastos, K.; Augenbraun, M.; Young, M.; Nowicki, M.; Cohen, M. H.; Peters, M. G.; Golub, E. T.; Szczech, L. | Not examining outcomes of interest
21879883 | Risk factors for nonadherence with Pap testing in HIV-infected women | J Womens Health (Larchmt) | Baranoski, A. S.; Horsburgh, C. R.; Cupples, L. A.; Aschengrau, A.; Stier, E. A. | Not examining outcomes of interest
109823318. Language: | Depression and Apathy Among People Living with HIV: Implications for Treatment of HIV Associated Neurocognitive Disorders | AIDS & Behavior | Bryant, Vaughn; Whitehead, Nicole; Burrell, Larry; Dotson, Vonetta; Cook, Robert; Malloy, Paul; Devlin, Kathryn; Cohen, Ronald | Not examining outcomes of interest
16511769 | HIV infection and bone mineral density in middle-aged women | Clin Infect Dis | Arnsten, J. H.; Freeman, R.; Howard, A. A.; Floris-Moore, M.; Santoro, N.; Schoenbaum, E. E. | Not examining outcomes of interest
21457540 | Comparison of intima-media thickness and ophthalmic artery resistance index for assessing subclinical atherosclerosis in HIV-1-infected patients | Cardiovasc Ultrasound | Grima, P.; Guido, M.; Chiavaroli, R.; De Donno, A.; Tana, M.; Zizza, A. | Not examining outcomes of interest
25711324 | Kidney disease in antiretroviral-naive HIV-positive adults with high CD4 counts: prevalence and predictors of kidney disease at enrolment in the INSIGHT Strategic Timing of AntiRetroviral Treatment (START) trial | HIV Med | Achhra, A. C.; Mocroft, A.; Ross, M. J.; Ryom, L.; Lucas, G. M.; Furrer, H.; Neuhaus, J.; Somboonwit, C.; Kelly, M.; Gatell, J. M.; Wyatt, C. M. | Not examining outcomes of interest
16251836 | Relative prevalence of comorbidities and treatment contraindications in HIV-mono-infected and HIV/HCV-co-infected veterans | Aids | Goulet, J. L.; Fultz, S. L.; McGinnis, K. A.; Justice, A. C. | Not examining outcomes of interest
22188140 | Racial patterns of extranodal natural killer/T-cell lymphoma, nasal type, in California: a population-based study | Br J Haematol | Ai, W. Z.; Chang, E. T.; Fish, K.; Fu, K.; Weisenburger, D. D.; Keegan, T. H. | Not examining outcomes of interest
22006469 | Associations of cardiovascular variables and HAART with cognition in middle-aged HIV-infected and uninfected women | J Neurovirol | Crystal, H. A.; Weedon, J.; Holman, S.; Manly, J.; Valcour, V.; Cohen, M.; Anastos, K.; Liu, C.; Mack, W. J.; Golub, E.; Lazar, J.; Ho, A.; Kreek, M. J.; Kaplan, R. C. | Not examining outcomes of interest
19684507 | HIV-infected persons continue to lose kidney function despite successful antiretroviral therapy | Aids | Choi, A. I.; Shlipak, M. G.; Hunt, P. W.; Martin, J. N.; Deeks, S. G. | Not examining outcomes of interest
22571839 | HIV-infected persons with bipolar disorder are less aware of memory deficits than HIV-infected persons without bipolar disorder | J Clin Exp Neuropsychol | Blackstone, K.; Tobin, A.; Posada, C.; Gouaux, B.; Grant, I.; Moore, D. J.; The Hiv Neurobehavioral Research Program, Hnrp | Not examining outcomes of interest
23023101 | Multimorbidity patterns in HIV-infected patients: the role of obesity in chronic disease clustering | J Acquir Immune Defic Syndr | Kim, D. J.; Westfall, A. O.; Chamot, E.; Willig, A. L.; Mugavero, M. J.; Ritchie, C.; Burkholder, G. A.; Crane, H. M.; Raper, J. L.; Saag, M. S.; Willig, J. H. | Not examining outcomes of interest
22132928 | Neurocognitive effects of HIV, hepatitis C, and substance use history | J Int Neuropsychol Soc | Devlin, K. N.; Gongvatana, A.; Clark, U. S.; Chasman, J. D.; Westbrook, M. L.; Tashima, K. T.; Navia, B.; Cohen, R. A. | Not examining outcomes of interest
24595021 | Select neurocognitive impairment in HIV-infected women: associations with HIV viral load, hepatitis C virus, and depression, but not leukocyte telomere length | PLoS One | Giesbrecht, C. J.; Thornton, A. E.; Hall-Patch, C.; Maan, E. J.; Cote, H. C.; Money, D. M.; Murray, M.; Pick, N. | Not examining outcomes of interest
19803714 | Elevated NT-pro-BNP levels are associated with comorbidities among HIV-infected women | AIDS Res Hum Retroviruses | Mansoor, A.; Althoff, K.; Gange, S.; Anastos, K.; Dehovitz, J.; Minkoff, H.; Kaplan, R.; Holman, S.; Lazar, J. M. | Not examining outcomes of interest
105411906. Language: | At-risk drinking and injection and sexual risk behaviors of HIV-positive injection drug users entering drug treatment in New York City | AIDS Patient Care & STDs | Arasteh, K.; Des Jarlais, D. C. | Not examining outcomes of interest
23061599 | The effect of unsuccessful treatment with peginterferon and ribavirin on the liver fibrosis course of HIV/HCV-coinfected patients | Curr HIV Res | Collazos, J.; Asensi, V.; de la Fuente, B.; Carton, J. A. | Not examining outcomes of interest
20662594 | Neurocognition, health-related reading literacy, and numeracy in medication management for HIV infection | AIDS Patient Care STDS | Waldrop-Valverde, D.; Jones, D. L.; Gould, F.; Kumar, M.; Ownby, R. L. | Not examining outcomes of interest
22564797 | Provider and patient correlates of provider decisions to recommend HCV treatment to HIV co-infected patients | J Int Assoc Physicians AIDS Care (Chic) | Wagner, G.; Osilla, K. C.; Garnett, J.; Ghosh-Dastidar, B.; Bhatti, L.; Witt, M.; Goetz, M. B. | Not examining outcomes of interest
24933093 | Taking it one day at a time: African American women aging with HIV and co-morbidities | AIDS Patient Care STDS | Warren-Jeanpiere, L.; Dillaway, H.; Hamilton, P.; Young, M.; Goparaju, L. | Not examining outcomes of interest
21431413 | Gender and age differences in quality of life and the impact of psychopathological symptoms among HIV-infected patients | AIDS and Behavior | Pereira, Marco; Canavarro, Maria Cristina | Not examining outcomes of interest
18018770 | Risk factors for acute liver enzyme abnormalities in HIV-hepatitis B virus-coinfected patients on antiretroviral therapy | Antivir Ther | Chauvel, O.; Lacombe, K.; Bonnard, P.; Lascoux-Combe, C.; Molina, J. M.; Miailhes, P.; Girard, P. M.; Carrat, F. | Not examining outcomes of interest
18681190 | Quality of life, symptomatology and healthcare utilization in HIV/HCV co-infected drug users in Miami | J Addict Dis | Baum, M. K.; Jayaweera, D. T.; Duan, R.; Sales, S.; Lai, S.; Rafie, C.; Regev, A.; Page, J. B.; Berkman, R.; Campa, A. | Not examining outcomes of interest
22127042 | Comorbidities and depression in older adults with HIV | Sex Health | Havlik, R. J.; Brennan, M.; Karpiak, S. E. | Not examining outcomes of interest
16048441 | Influence of depression and HIV serostatus on the neuropsychological performance of injecting drug users | Psychiatry Clin Neurosci | Waldrop-Valverde, D.; Ownby, R. L.; Kumar, M. | Not examining outcomes of interest
105651914. Language: | Service utilization and cognitive complaints in adults with HIV: results from a statewide survey | Journal of HIV/AIDS & Social Services | Okonkwo, O.; Vance, D.; Antia, L.; Smith, B.; Blanshan, S.; Heirs, K.; Bodner, E. | Not examining outcomes of interest
25742054 | Trauma history in African-American women living with HIV: effects on psychiatric symptom severity and religious coping | AIDS Care | Brownley, J. R. | Not examining outcomes of interest
106517301. Language: | Perceptions of support among older adults with HIV | Research on Aging | Shippy, R. A. and Karpiak, S. E. | Not examining outcomes of interest
19803620 | Examining family networks of HIV+ women in drug recovery: challenges and opportunities | Families, Systems & Health: The Journal of Collaborative Family HealthCare | Mitrani, V. B.; Weiss-Laxer, N. S.; Ow, C. E.; Burns, M. J.; Ross-Russell, S.; Feaster, D. J. | Not examining outcomes of interest
26669792 | Hepatitis C Direct Acting Antiviral Therapies in a New York City HIV/AIDS Special Needs Plan: Uptake and Barriers | AIDS Patient Care & STDs | | Not examining outcomes of interest
23277233 | Differential medication nonadherence and illness beliefs in co-morbid HIV and type 2 diabetes | J Behav Med | Batchelder, A. W.; Gonzalez, J. S.; Berg, K. M. | Not examining outcomes of interest
21058961 | Excess mortality among HIV-infected patients diagnosed with substance use dependence or abuse receiving care in a fully integrated medical care program | Alcohol Clin Exp Res | DeLorenze, G. N.; Weisner, C.; Tsai, A. L.; Satre, D. D.; Quesenberry, C. P., Jr. | Not examining outcomes of interest
15695694 | Long-term molecular analysis of tuberculosis strains in alabama, a state characterized by a largely indigenous, low-risk population | J Clin Microbiol | Kempf, M. C.; Dunlap, N. E.; Lok, K. H.; Benjamin, W. H., Jr.; Keenan, N. B.; Kimerling, M. E. | Not examining outcomes of interest
20664016 | Association between systemic inflammation and incident diabetes in HIV-infected patients after initiation of antiretroviral therapy | Diabetes Care | Brown, T. T.; Tassiopoulos, K.; Bosch, R. J.; Shikuma, C.; McComsey, G. A. | Not examining outcomes of interest
25404005 | Self-predictions of prospective memory in HIV-associated neurocognitive disorders: evidence of a metamemory deficit | Arch Clin Neuropsychol | Casaletto, K. B.; Doyle, K. L.; Weber, E.; Woods, S. P. | Not examining outcomes of interest
22614744 | Bipolar disorder is associated with HIV transmission risk behavior among patients in treatment for HIV | AIDS Behav | Meade, C. S.; Bevilacqua, L. A.; Key, M. D. | Not examining outcomes of interest
18376387 | Classic Kaposi Sarcoma in the United States over the last two decades: a clinicopathologic and molecular study of 438 non-HIV-related Kaposi Sarcoma patients with comparison to HIV-related Kaposi Sarcoma | Mod Pathol | Hiatt, K. M.; Nelson, A. M.; Lichy, J. H.; Fanburg-Smith, J. C. | Not examining outcomes of interest
86060553 | HIV-Related Stigma as a Mediator of the Relation Between Multiple-Minority Status and Mental Health Burden in an Aging HIV-Positive Population | Journal of HIV/AIDS & Social Services | Storholm, Erik David; Halkitis, Perry N.; Kupprat, Sandra A.; Hampton, Melvin C.; Palamar, Joseph J.; Brennan-Ing, Mark; Karpiak, Stephen | Not examining outcomes of interest
23169503 | Pegylated liposomal doxorubicin, rituximab, cyclophosphamide, vincristine, and prednisone in AIDS-related lymphoma: AIDS Malignancy Consortium Study 047 | J Clin Oncol | Levine, A. M.; Noy, A.; Lee, J. Y.; Tam, W.; Ramos, J. C.; Henry, D. H.; Parekh, S.; Reid, E. G.; Mitsuyasu, R.; Cooley, T.; Dezube, B. J.; Ratner, L.; Cesarman, E.; Tulpule, A. | Not examining outcomes of interest
24499953 | Correlates of HIV sustained viral suppression in HIV/hepatitis C virus coinfected patients: possible role of the hepatitis C virus sustained viral response | Aids | Bani-Sadr, F.; Loko, M. A.; Pambrun, E.; Winnock, M.; Carrieri, P.; Gilbert, C.; Duvivier, C.; Bouchaud, O.; Gervais, A.; Dabis, F.; Salmon, D. | Not examining outcomes of interest
20105080 | Hepatitis C virus (HCV) quasispecies complexity and selection in HCV/HIV-coinfected subjects treated with interferon-based regimens | J Infect Dis | Sherman, K. E.; Rouster, S. D.; Stanford, S.; Blackard, J. T.; Shire, N.; Koziel, M.; Peters, M.; Chung, R. T. | Not examining outcomes of interest
25417712 | Short Communication: HIV RNA Levels Predict AIDS-Defining and Non-AIDS-Defining Cancers After Antiretroviral Therapy Initiation Among HIV-Infected Adults | AIDS Res Hum Retroviruses | Crum-Cianflone, N. F. | Not examining outcomes of interest
20658749 | Changes in lipids and lipoprotein particle concentrations after interruption of antiretroviral therapy | J Acquir Immune Defic Syndr | Lampe, F. C.; Duprez, D. A.; Kuller, L. H.; Tracy, R.; Otvos, J.; Stroes, E.; Cooper, D. A.; Hoy, J.; Paton, N. I.; Friis-Moller, N.; Neuhaus, J.; Liappis, A. P.; Phillips, A. N. | Not examining outcomes of interest
23613008 | Progressive cerebral injury in the setting of chronic HIV infection and antiretroviral therapy | J Neurovirol | Gongvatana, A.; Harezlak, J.; Buchthal, S.; Daar, E.; Schifitto, G.; Campbell, T.; Taylor, M.; Singer, E.; Algers, J.; Zhong, J.; Brown, M.; McMahon, D.; So, Y. T.; Mi, D.; Heaton, R.; Robertson, K.; Yiannoutsos, C.; Cohen, R. A.; Navia, B. | Not examining outcomes of interest
17560067 | Analysis of CCR5, CCR2, SDF1 and RANTES gene polymorphisms in subjects with HIV-related PML and not determined leukoencephalopathy | Biomed Pharmacother | Guerini, F. R.; Delbue, S.; Zanzottera, M.; Agliardi, C.; Saresella, M.; Mancuso, R.; Maserati, R.; Marchioni, E.; Gori, A.; Ferrante, P. | Not examining outcomes of interest
22088609 | Pain anxiety, acceptance, and outcomes among individuals with HIV and chronic pain: a preliminary investigation | Behav Res Ther | Huggins, J. L.; Bonn-Miller, M. O.; Oser, M. L.; Sorrell, J. T.; Trafton, J. A. | Not examining outcomes of interest
25723139 | Risk of Liver Enzyme Elevation During Treatment With Ritonavir-Boosted Protease Inhibitors Among HIV-Monoinfected and HIV/HCV-Coinfected Patients | J Acquir Immune Defic Syndr | Lapadula, G.; Costarelli, S.; Chatenoud, L.; Castelli, F.; Astuti, N.; Di Giambenedetto, S.; Quiros-Roldan, E.; Sighinolfi, L.; Ladisa, N.; Di Pietro, M.; Zoncada, A.; Di Filippo, E.; Gori, A.; Nasta, P.; Torti, C. | Not examining outcomes of interest
18684404 | Fatigue in HIV/AIDS patients with comorbidities | Appl Nurs Res | Corless, I. B.; Voss, J. G.; Nicholas, P. K.; Bunch, E. H.; Bain, C. A.; Coleman, C.; Dole, P. J.; Eller, L. S.; Hamilton, M. J.; Holzemer, W. L.; Kemppainen, J. K.; Kirksey, K. M.; Sefcik, E. F.; Nokes, K. M.; Tsais, Y. F.; Reynolds, N. R.; Wantland, D. J.; Mc Gibbon, C.; Davis, S. M.; Mendez, M. R.; Valencia, C. P. | Not examining outcomes of interest
103777801. Language: | Hearing loss among HIV-seropositive and HIV-seronegative men and women | JAMA Otolaryngology-Head & Neck Surgery | | Not examining outcomes of interest
16908797 | Liver-related deaths in persons infected with the human immunodeficiency virus: the D:A:D study | Arch Intern Med | Weber, R.; Sabin, C. A.; Friis-Moller, N.; Reiss, P.; El-Sadr, W. M.; Kirk, O.; Dabis, F.; Law, M. G.; Pradier, C.; De Wit, S.; Akerlund, B.; Calvo, G.; Monforte, Ad; Rickenbach, M.; Ledergerber, B.; Phillips, A. N.; Lundgren, J. D. | Not examining outcomes of interest
21402550 | Effects of antiretroviral therapy on immune function of HIV-infected adults with pulmonary tuberculosis and CD4+ >350 cells/mm3 | J Infect Dis | Lancioni, C. L.; Mahan, C. S.; Johnson, D. F.; Walusimbi, M.; Chervenak, K. A.; Nalukwago, S.; Charlebois, E.; Havlir, D.; Mayanja-Kizza, H.; Whalen, C. C.; Boom, W. H. | Not examining outcomes of interest
20133265 | Long-term impact of efavirenz on neuropsychological performance and symptoms in HIV-infected individuals (ACTG 5097s) | HIV Clin Trials | Clifford, D. B.; Evans, S.; Yang, Y.; Acosta, E. P.; Ribaudo, H.; Gulick, R. M. | Not examining outcomes of interest
17974644 | Comorbidities in older patients with HIV: a retrospective study | J Am Dent Assoc | Magalhaes, M. G.; Greenberg, B.; Hansen, H.; Glick, M. | Not examining outcomes of interest
23442493 | HIV status among patients with tuberculosis and HIV testing practices by Connecticut health care providers | J Int Assoc Provid AIDS Care | Clark, I. T.; Lobato, M. N.; Gutierrez, J.; Sosa, L. E. | Not examining outcomes of interest
16280701 | A population-based analysis of temporal trends in the incidence of squamous anal canal cancer in relation to the HIV epidemic | J Acquir Immune Defic Syndr | Chiao, E. Y.; Krown, S. E.; Stier, E. A.; Schrag, D. | Not examining outcomes of interest
18593347 | Hepatitis C virus coinfection does not affect CD4 restoration in HIV-infected patients after initiation of antiretroviral therapy | AIDS Res Hum Retroviruses | Yacisin, K.; Maida, I.; Rios, M. J.; Soriano, V.; Nunez, M. | Not examining outcomes of interest
20854173 | Directly observed antiretroviral therapy in substance abusers receiving methadone maintenance therapy does not cause increased drug resistance | AIDS Res Hum Retroviruses | Brust, J. C.; Litwin, A. H.; Berg, K. M.; Li, X.; Heo, M.; Arnsten, J. H. | Not examining outcomes of interest
18668226 | The apolipoprotein E epsilon4 allele and memory performance in HIV-1 seropositive subjects: differences at baseline but not after acute oral lorazepam challenge | Psychopharmacology (Berl) | Pomara, N.; Belzer, K. D.; Silva, R.; Cooper, T. B.; Sidtis, J. J. | Not examining outcomes of interest
23329164 | Detection of anti-tat antibodies in CSF of individuals with HIV-associated neurocognitive disorders | J Neurovirol | Bachani, M.; Sacktor, N.; McArthur, J. C.; Nath, A.; Rumbaugh, J. | Not examining outcomes of interest
22670566 | Active cocaine use is associated with lack of HIV-1 virologic suppression independent of nonadherence to antiretroviral therapy: use of a rapid screening tool during routine clinic visits | AIDS Care | Rasbach, D. A.; Desruisseau, A. J.; Kipp, A. M.; Stinnette, S.; Kheshti, A.; Shepherd, B. E.; Sterling, T. R.; Hulgan, T.; McGowan, C. C.; Qian, H. Z. | Not examining outcomes of interest
16176898 | Gender differences among HIV-positive methadone maintenance patients enrolled in a medication adherence trial | AIDS Care | Haug, N. A.; Sorensen, J. L.; Lollo, N. D.; Gruber, V. A.; Delucchi, K. L.; Hall, S. M. | Not examining outcomes of interest
24977377 | Health insurance coverage for persons in HIV care, 2006-2012 | J Acquir Immune Defic Syndr | Yehia, B. R.; Fleishman, J. A.; Agwu, A. L.; Metlay, J. P.; Berry, S. A.; Gebo, K. A. | Not examining outcomes of interest
22332854 | Shotgunning' in a population of patients with severe mental illness and comorbid substance use disorders | Am J Addict | Welsh, C.; Goldberg, R.; Tapscott, S.; Medoff, D.; Rosenberg, S.; Dixon, L. | Not examining outcomes of interest
21818528 | A closer look at depression and its relationship to HIV antiretroviral adherence | Ann Behav Med | Wagner, G. J.; Goggin, K.; Remien, R. H.; Rosen, M. I.; Simoni, J.; Bangsberg, D. R.; Liu, H. | Not examining outcomes of interest
24625188 | Alcohol and associated characteristics among older persons living with human immunodeficiency virus on antiretroviral therapy | Subst Abus | Williams, E. C.; Bradley, K. A.; Balderson, B. H.; McClure, J. B.; Grothaus, L.; McCoy, K.; Rittmueller, S. E.; Catz, S. L. | Not examining outcomes of interest
23924399 | Associations between the legal context of HIV, perceived social capital, and HIV antiretroviral adherence in North America | BMC Public Health | Phillips, J. C.; Webel, A.; Rose, C. D.; Corless, I. B.; Sullivan, K. M.; Voss, J.; Wantland, D.; Nokes, K.; Brion, J.; Chen, W. T.; Iipinge, S.; Eller, L. S.; Tyer-Viola, L.; Rivero-Mendez, M.; Nicholas, P. K.; Johnson, M. O.; Maryland, M.; Kemppainen, J.; Portillo, C. J.; Chaiphibalsarisdi, P.; Kirksey, K. M.; Sefcik, E.; Reid, P.; Cuca, Y.; Huang, E.; Holzemer, W. L. | Not examining outcomes of interest
16470122 | Effect of hepatitis C coinfection on discontinuation and modification of initial HAART in primary HIV care | Aids | Hooshyar, D.; Napravnik, S.; Miller, W. C.; Eron, J. J., Jr. | Not examining outcomes of interest
22311149 | Predicting depression in mothers with and without HIV: the role of social support and family dynamics | AIDS Behav | Dyer, T. P.; Stein, J. A.; Rice, E.; Rotheram-Borus, M. J. | Not examining outcomes of interest
25574956 | Relationships of pulmonary function, inflammation, and T-cell activation and senescence in an HIV-infected cohort | Aids | Fitzpatrick, M. E.; Singh, V.; Bertolet, M.; Lucht, L.; Kessinger, C.; Michel, J.; Logar, A.; Weinman, R.; McMahon, D.; Norris, K. A.; Vallejo, A. N.; Morris, A. | Not examining outcomes of interest
16496089 | Social support, disclosure, and use of antiretroviral therapy | AIDS Behav | Waddell, E. N.; Messeri, P. A. | Not examining outcomes of interest
22135046 | The effect of HIV and HPV coinfection on cervical COX-2 expression and systemic prostaglandin E2 levels | Cancer Prev Res (Phila) | Fitzgerald, D. W.; Bezak, K.; Ocheretina, O.; Riviere, C.; Wright, T. C.; Milne, G. L.; Zhou, X. K.; Du, B.; Subbaramaiah, K.; Byrt, E.; Goodwin, M. L.; Rafii, A.; Dannenberg, A. J. | Not examining outcomes of interest
22156964 | Vitamin D deficiency and persistent proteinuria among HIV-infected and uninfected injection drug users | Aids | Estrella, M. M.; Kirk, G. D.; Mehta, S. H.; Brown, T. T.; Fine, D. M.; Atta, M. G.; Lucas, G. M. | Not examining outcomes of interest
21717822 | Policosanol for managing human immunodeficiency virus-related dyslipidemia in a medically underserved population: a randomized, controlled clinical trial | Altern Ther Health Med | Swanson, B.; Keithley, J. K.; Sha, B. E.; Fogg, L.; Nerad, J.; Novak, R. M.; Adeyemi, O.; Spear, G. T. | Not examining outcomes of interest
20693741 | Insurance coverage among people living with combined HIV/AIDS, chronic mental illness, and substance abuse disorders | J Health Care Poor Underserved | Conover, C. J.; Weaver, M.; Arno, P.; Ang, A.; Ettner, S. L. | Not examining outcomes of interest
25563775 | Virtual intervention to support self-management of antiretroviral therapy among people living with HIV | J Med Internet Res | Cote, J.; Godin, G.; Ramirez-Garcia, P.; Rouleau, G.; Bourbonnais, A.; Gueheneuc, Y. G.; Tremblay, C.; Otis, J. | Not examining outcomes of interest
25781903 | Antiretroviral Non-Adherence is Associated With a Retrieval Profile of Deficits in Verbal Episodic Memory | Clin Neuropsychol | Obermeit, L. C.; Morgan, E. E.; Casaletto, K. B.; Grant, I.; Woods, S. P. | Not examining outcomes of interest
18071894 | A daily process investigation of alcohol-involved sexual risk behavior among economically disadvantaged problem drinkers living with HIV/AIDS | AIDS Behav | Barta, W. D.; Portnoy, D. B.; Kiene, S. M.; Tennen, H.; Abu-Hasaballah, K. S.; Ferrer, R. | Not examining outcomes of interest
24524493 | A multisite study of the prevalence of HIV with rapid testing in mental health settings | Am J Public Health | Blank, M. B.; Himelhoch, S. S.; Balaji, A. B.; Metzger, D. S.; Dixon, L. B.; Rose, C. E.; Oraka, E.; Davis-Vogel, A.; Thompson, W. W.; Heffelfinger, J. D. | Not examining outcomes of interest
16036240 | Determinants of HAART discontinuation among injection drug users | AIDS Care | Kerr, T.; Marshall, A.; Walsh, J.; Palepu, A.; Tyndall, M.; Montaner, J.; Hogg, R.; Wood, E. | Not examining outcomes of interest
105659740. Language: | Exploring research issues: in using a random sampling plan with highly marginalized populations | Journal of Multicultural Nursing & Health (JMCNH) | Nokes, K. M.; Nwakeze, P. C. | Not examining outcomes of interest
16706710 | Social stigma concerns and HIV medication adherence | AIDS Patient Care STDS | Rintamaki, L. S.; Davis, T. C.; Skripkauskas, S.; Bennett, C. L.; Wolf, M. S. | Not examining outcomes of interest
109373197. Language: | The Contribution of Missed Clinic Visits to Disparities in HIV Viral Load Outcomes | American Journal of Public Health | | Not examining outcomes of interest
17916167 | Evidence-based, multifactorial approach to addressing non-adherence to antiretroviral therapy and improving standards of care | Intern Med J | Herrmann, S.; McKinnon, E.; John, M.; Hyland, N.; Martinez, O. P.; Cain, A.; Turner, K.; Coombs, A.; Manolikos, C.; Mallal, S. | Not examining outcomes of interest
21239994 | The impact of the AIDS Drug Assistance Program (ADAP) on use of highly active antiretroviral and antihypertensive therapy among HIV-infected women | J Acquir Immune Defic Syndr | Yi, T.; Cocohoba, J.; Cohen, M.; Anastos, K.; DeHovitz, J. A.; Kono, N.; Hanna, D. B.; Hessol, N. A. | Not examining outcomes of interest
18366327 | The Events in Care Screening Questionnaire (ECSQ): a new tool to identify needs and concerns of people with HIV/AIDS | AIDS Patient Care STDS | Patel, S.; Weiss, E.; Chhabra, R.; Ryniker, L.; Adsuar, R.; Carness, J.; Kahalas, W.; Delamarter, C.; Feldman, I. S.; Delorenzo, J. P.; Tanner, E.; Rapkin, B. | Not examining outcomes of interest
106545923. Language: | Lipodystrophy-associated symptoms and medication adherence in HIV/AIDS | AIDS Patient Care & STDs | Corless, I. B.; Kirksey, K. M.; Kemppainen, J.; Nicholas, P. K.; McGibbon, C.; Davis, S. M.; Dolan, S. | Not examining outcomes of interest
21803164 | Impact of apolipoprotein E epsilon4 and HIV on cognition and brain atrophy: antagonistic pleiotropy and premature brain aging | Neuroimage | Chang, L.; Andres, M.; Sadino, J.; Jiang, C. S.; Nakama, H.; Miller, E.; Ernst, T. | Not examining outcomes of interest
17342656 | Do HIV care providers appropriately manage hepatitis B in coinfected patients treated with antiretroviral therapy? | Clin Infect Dis | Jain, M. K.; Opio, C. K.; Osuagwu, C. C.; Pillai, R.; Keiser, P.; Lee, W. M. | Not examining outcomes of interest
19444675 | HAART receipt and viral suppression among HIV-infected patients with co-occurring mental illness and illicit drug use | AIDS Care | Chander, G.; Himelhoch, S.; Fleishman, J. A.; Hellinger, J.; Gaist, P.; Moore, R. D.; Gebo, K. A. | Not examining outcomes of interest
25958200 | Strategies to uncover undiagnosed HIV infection among heterosexuals at high risk and link them to HIV care with high retention: a ‘seek, test, treat, and retain’ study | BMC Public Health | Gwadz, M. | Not examining outcomes of interest
22101218 | Rationale, study design and sample characteristics of a randomized controlled trial of directly administered antiretroviral therapy for HIV-infected prisoners transitioning to the community - a potential conduit to improved HIV treatment outcomes | Contemp Clin Trials | Saber-Tehrani, A. S.; Springer, S. A.; Qiu, J.; Herme, M.; Wickersham, J.; Altice, F. L. | Not examining outcomes of interest
18243579 | Drug use and other risk factors related to lower body mass index among HIV-infected individuals | Drug Alcohol Depend | Quach, L. A.; Wanke, C. A.; Schmid, C. H.; Gorbach, S. L.; Mwamburi, D. M.; Mayer, K. H.; Spiegelman, D.; Tang, A. M. | Not examining outcomes of interest
22003405 | IL28B alleles exert an additive dose effect when applied to HCV-HIV coinfected persons undergoing peginterferon and ribavirin therapy | PLoS One | Dayyeh, B. K.; Gupta, N.; Sherman, K. E.; de Bakker, P. I.; Chung, R. T. | Not examining outcomes of interest
22183836 | Ongoing sexually transmitted disease acquisition and risk-taking behavior among US HIV-infected patients in primary care: implications for prevention interventions | Sex Transm Dis | Mayer, K. H.; Bush, T.; Henry, K.; Overton, E. T.; Hammer, J.; Richardson, J.; Wood, K.; Conley, L.; Papp, J.; Caliendo, A. M.; Patel, P.; Brooks, J. T. | Not examining outcomes of interest
19770624 | Short-term ezetimibe is well tolerated and effective in combination with statin therapy to treat elevated LDL cholesterol in HIV-infected patients | Aids | Chow, D.; Chen, H.; Glesby, M. J.; Busti, A.; Souza, S.; Andersen, J.; Kohrs, S.; Wu, J.; Koletar, S. L. | Not examining outcomes of interest
16182404 | Slower fibrosis progression in HIV/HCV-coinfected patients with successful HIV suppression using antiretroviral therapy | J Hepatol | Brau, N.; Salvatore, M.; Rios-Bedoya, C. F.; Fernandez-Carbia, A.; Paronetto, F.; Rodriguez-Orengo, J. F.; Rodriguez-Torres, M. | Not examining outcomes of interest
23985908 | Classical molecular tests using urine samples as a potential screening tool for human papillomavirus detection in human immunodeficiency virus-infected women | J Clin Microbiol | Munoz, M.; Camargo, M.; Soto-De Leon, S. C.; Sanchez, R.; Pineda-Pena, A. C.; Perez-Prados, A.; Patarroyo, M. E.; Patarroyo, M. A. | Not examining outcomes of interest
104177412. Language: | An International Systematic Review and Meta-analysis of Multisession Psychosocial Interventions Compared with Educational or Minimal Interventions on the HIV Sex Risk Behaviors of People Who Use Drugs | AIDS & Behavior | Meader, Nicholas; Semaan, Salaam; Halton, Marie; Bhatti, Henna; Chan, Melissa; Llewellyn, Alexis; Jarlais, Don | Not examining outcomes of interest
19998643 | Disparities in antiretroviral prescribing for blacks and whites in the United States | J Natl Med Assoc | Oramasionwu, C. U.; Skinner, J.; Ryan, L.; Frei, C. R. | Not examining outcomes of interest
20070011 | Access to regular HIV care and disease progression among black African immigrants | J Natl Med Assoc | Page, L. C.; Goldbaum, G.; Kent, J. B.; Buskin, S. E. | Not examining outcomes of interest
21239360 | Monthly unannounced pill counts for monitoring HIV treatment adherence: tests for self-monitoring and reactivity effects | HIV Clin Trials | Kalichman, S. C.; Amaral, C.; Swetsze, C.; Eaton, L.; Kalichman, M. O.; Cherry, C.; Detorio, M.; Caliendo, A. M.; Schinazi, R. F. | Not examining outcomes of interest
21498150 | Factors associated with complete adherence to HIV combination antiretroviral therapy | HIV Clin Trials | Juday, T.; Gupta, S.; Grimm, K.; Wagner, S.; Kim, E. | Not examining outcomes of interest
24070643 | Abuse and mental health concerns among HIV-infected Haitian women living in the United States | J Assoc Nurses AIDS Care | Glemaud, M.; Illa, L.; Echenique, M.; Bustamente-Avellaneda, V.; Gazabon, S.; Villar-Loubet, O.; Rodriguez, A.; Potter, J.; Messick, B.; Jayaweera, D. T.; Boulanger, C.; Kolber, M. A. | Not examining outcomes of interest
24568654 | Abuse and resilience in relation to HAART medication adherence and HIV viral load among women with HIV in the United States | AIDS Patient Care STDS | Dale, S.; Cohen, M.; Weber, K.; Cruise, R.; Kelso, G.; Brody, L. | Not examining outcomes of interest
16109981 | Acquired rifamycin resistance with twice-weekly treatment of HIV-related tuberculosis | Am J Respir Crit Care Med | Burman, W.; Benator, D.; Vernon, A.; Khan, A.; Jones, B.; Silva, C.; Lahart, C.; Weis, S.; King, B.; Mangura, B.; Weiner, M.; El-Sadr, W. | Not examining outcomes of interest
23195670 | Comparison of functional status instruments in HIV-infected adults on effective antiretroviral therapy | HIV Clin Trials | Erlandson, K. M.; Allshouse, A. A.; Jankowski, C. M.; Duong, S.; Mawhinney, S.; Kohrt, W. M.; Campbell, T. B. | Not examining outcomes of interest
17415019 | Factors affecting reproductive hormones in HIV-infected, substance-using middle-aged women | Menopause | Santoro, N.; Lo, Y.; Moskaleva, G.; Arnsten, J. H.; Floris-Moore, M.; Howard, A. A.; Adel, G.; Zeitlian, G.; Schoenbaum, E. E. | Not examining outcomes of interest
18727992 | Frequency of discussing HIV prevention and care topics with patients with HIV: influence of physician gender, race/ethnicity, and practice characteristics | Gend Med | Gardner, L. I.; Metsch, L.; Strathdee, S. A.; del Rio, C.; Mahoney, P.; Holmberg, S. D. | Not examining outcomes of interest
20162495 | Neurocognitive functioning in HIV-1 infection: effects of cerebrovascular risk factors and age | Clin Neuropsychol | Foley, J.; Ettenhofer, M.; Wright, M. J.; Siddiqi, I.; Choi, M.; Thames, A. D.; Mason, K.; Castellon, S.; Hinkin, C. H. | Not examining outcomes of interest
15793937 | Perceived adverse effects of antiretroviral therapy | J Pain Symptom Manage | Johnson, M. O.; Charlebois, E.; Morin, S. F.; Catz, S. L.; Goldstein, R. B.; Remien, R. H.; Rotheram-Borus, M. J.; Mickalian, J. D.; Kittel, L.; Samimy-Muzaffar, F.; Lightfoot, M. A.; Gore-Felton, C.; Chesney, A. | Not examining outcomes of interest
22731608 | Planning deficits in HIV-associated neurocognitive disorders: component processes, cognitive correlates, and implications for everyday functioning | J Clin Exp Neuropsychol | Cattie, J. E.; Doyle, K.; Weber, E.; Grant, I.; Woods, S. P. | Not examining outcomes of interest
22629383 | Soluble and cell-associated insulin receptor dysfunction correlates with severity of HAND in HIV-infected women | PLoS One | Gerena, Y.; Skolasky, R. L.; Velez, J. M.; Toro-Nieves, D.; Mayo, R.; Nath, A.; Wojna, V. | Not examining outcomes of interest
22876739 | Testing a service integration model: results from the HIV/AIDS initiative, ConnectHIV | AIDS Care | Rogers, S. J.; De Palomo, F.; Little, S. E.; Woldehanna, S. | Not examining outcomes of interest
19050385 | Trends in the incidence of cancers among HIV-infected persons and the impact of antiretroviral therapy: a 20-year cohort study | Aids | Crum-Cianflone, N.; Hullsiek, K. H.; Marconi, V.; Weintrob, A.; Ganesan, A.; Barthel, R. V.; Fraser, S.; Agan, B. K.; Wegner, S. | Not examining outcomes of interest
22781176 | Antiretroviral therapy adherence and drug-drug interactions in the aging HIV population | Aids | Nachega, J. B.; Hsu, A. J.; Uthman, O. A.; Spinewine, A.; Pham, P. A. | Not examining outcomes of interest
2009-05344-007 | Association of child care burden and household composition with adherence to highly active antiretroviral therapy in the Women's Interagency HIV Study | AIDS Patient Care and STDs | Merenstein, Daniel; Schneider, Michael F.; Cox, Christopher; Schwartz, Rebecca; Weber, Kathleen; Robison, Esther; Gandhi, Monica; Richardson, Jean; Plankey, Michael W. | Not examining outcomes of interest
18418794 | Cigarette smoking is an independent predictor of nonadherence in HIV-infected individuals receiving highly active antiretroviral therapy | Nicotine Tob Res | Shuter, J.; Bernstein, S. L. | Not examining outcomes of interest
15793371 | Correlation of a brief perceived stress measure with nonadherence to antiretroviral therapy over time | J Acquir Immune Defic Syndr | French, T.; Weiss, L.; Waters, M.; Tesoriero, J.; Finkelstein, R.; Agins, B. | Not examining outcomes of interest
109824258. Language: | Environmental Influences on HIV Medication Adherence: The Role of Neighborhood Disorder | American Journal of Public Health | Surratt, Hilary L.; Kurtz, Steven P.; Levi-Minzi, Maria A.; Minxing, Chen | Not examining outcomes of interest
106422103. Language: | Long-term adherence to first-line highly active antiretroviral therapy in a hospital-based cohort: predictors and impact on virologic response and relapse | AIDS Patient Care & STDs | Parruti, G.; Manzoli, L.; Marani Toro, P.; D'Amico, G.; Rotolo, S.; Graziani, V.; Schioppa, F.; Consorte, A.; Alterio, L.; Mariani Toro, G.; Boyle, B. A. | Not examining outcomes of interest
23918244 | Methadone maintenance therapy decreases the rate of antiretroviral therapy discontinuation among HIV-positive illicit drug users | AIDS Behav | Reddon, H.; Milloy, M. J.; Simo, A.; Montaner, J.; Wood, E.; Kerr, T. | Not examining outcomes of interest
105363820. Language: | Prevalence and clinical implications of interactive toxicity beliefs regarding mixing alcohol and antiretroviral therapies among people living with HIV/AIDS | AIDS Patient Care & STDs | Kalichman, S. C.; Amaral, C. M.; White, D.; Swetsze, C.; Pope, H.; Kalichman, M. O.; Cherry, C.; Eaton, L. | Not examining outcomes of interest
22722882 | Relationship of Medication Management Test-Revised (MMT-R) performance to neuropsychological functioning and antiretroviral adherence in adults with HIV | AIDS Behav | Patton, D. E.; Woods, S. P.; Franklin, D., Jr.; Cattie, J. E.; Heaton, R. K.; Collier, A. C.; Marra, C.; Clifford, D.; Gelman, B.; McArthur, J.; Morgello, S.; Simpson, D.; McCutchan, J. A.; Grant, I. | Not examining outcomes of interest
23199190 | Sadness in the SUN: using computerized screening to analyze correlates of depression and adherence in HIV-infected adults in the United States | AIDS Patient Care STDS | Tedaldi, E. M.; van den Berg-Wolf, M.; Richardson, J.; Patel, P.; Durham, M.; Hammer, J.; Henry, K.; Metzler, S.; Onen, N.; Conley, L.; Wood, K.; Brooks, J. T.; Buchacz, K. | Not examining outcomes of interest
22223595 | Sequential antiretroviral adherence measurement using electronic bottle cap monitors in a cohort of HIV-infected adults | J Int Assoc Physicians AIDS Care (Chic) | Shuter, J.; Sarlo, J. A.; Stubbs, R. O.; Rode, R. A.; Zingman, B. S. | Not examining outcomes of interest
105363824. Language: | The impact of neuropsychological functioning on adherence to HAART in HIV-infected substance abuse patients | AIDS Patient Care & STDs | Applebaum, A. J.; Reilly, L. C.; Gonzalez, J. S.; Richardson, M. A.; Leveroni, C. L.; Safren, S. A. | Not examining outcomes of interest
19260772 | Utilization of medical treatments and adherence to antiretroviral therapy among HIV-positive adults with histories of childhood sexual abuse | AIDS Patient Care STDS | Meade, C. S.; Hansen, N. B.; Kochman, A.; Sikkema, K. J. | Not examining outcomes of interest
106521802. Language: | Patient-clinician relationships and treatment system effects on HIV medication adherence | AIDS & Behavior | Ingersoll, K. S.; Heckman, C. J. | Not examining outcomes of interest
106440668. Language: | Supportive relationships and medication adherence in HIV-infected, low-income Latinos | Western Journal of Nursing Research | van Servellen, G.; Lombardi, E. | Not examining outcomes of interest
106471557. Language: | To take or not to take: decision-making about antiretroviral treatment in people living with HIV/AIDS | AIDS Patient Care & STDs | Kremer, H.; Ironson, G.; Schneiderman, N.; Hautzinger, M. | Not examining outcomes of interest
17449216 | HIV seropositive drug users' attitudes towards partner notification (PCRS): results from the SHIELD study in Baltimore, Maryland | Patient Educ Couns | Tobin, K. E.; Muessig, K. E.; Latkin, C. A. | Not examining outcomes of interest
24500175 | Factors associated with delayed hepatitis B viral suppression on tenofovir among patients coinfected with HBV-HIV in the CNICS cohort | J Acquir Immune Defic Syndr | Kim, H. N.; Rodriguez, C. V.; Van Rompaey, S.; Eron, J. J.; Thio, C. L.; Crane, H. M.; Overton, E. T.; Saag, M. S.; Martin, J.; Geng, E.; Mugavero, M.; Rodriguez, B.; Mathews, W. C.; Boswell, S.; Moore, R.; Kitahata, M. M. | Not examining outcomes of interest
23382997 | Frailty, HIV infection, and mortality in an aging cohort of injection drug users | PLoS One | Piggott, D. A.; Muzaale, A. D.; Mehta, S. H.; Brown, T. T.; Patel, K. V.; Leng, S. X.; Kirk, G. D. | Not examining outcomes of interest
24831517 | HIV-infected individuals with low CD4/CD8 ratio despite effective antiretroviral therapy exhibit altered T cell subsets, heightened CD8+ T cell activation, and increased risk of non-AIDS morbidity and mortality | PLoS Pathog | Serrano-Villar, S.; Sainz, T.; Lee, S. A.; Hunt, P. W.; Sinclair, E.; Shacklett, B. L.; Ferre, A. L.; Hayes, T. L.; Somsouk, M.; Hsue, P. Y.; Van Natta, M. L.; Meinert, C. L.; Lederman, M. M.; Hatano, H.; Jain, V.; Huang, Y.; Hecht, F. M.; Martin, J. N.; McCune, J. M.; Moreno, S.; Deeks, S. G. | Not examining outcomes of interest
16199396 | HIV-risk factors for midlife and older women | Gerontologist | Neundorfer, M. M.; Harris, P. B.; Britton, P. J.; Lynch, D. A. | Not examining outcomes of interest
19410107 | Is intimate partner violence associated with HIV infection among women in the United States? | Gen Hosp Psychiatry | Sareen, J.; Pagura, J.; Grant, B. | Not examining outcomes of interest
17031318 | Late diagnosis of HIV infection: trends, prevalence, and characteristics of persons whose HIV diagnosis occurred within 12 months of developing AIDS | J Acquir Immune Defic Syndr | Schwarcz, S.; Hsu, L.; Dilley, J. W.; Loeb, L.; Nelson, K.; Boyd, S. | Not examining outcomes of interest
19564517 | Demographic variations in HIV testing history among emergency department patients: implications for HIV screening in US emergency departments | J Med Screen | Merchant, R. C.; Catanzaro, B. M.; Seage, G. R., 3rd; Mayer, K. H.; Clark, M. A.; Degruttola, V. G.; Becker, B. M. | Not examining outcomes of interest
20546501 | The impact of HIV/HCV co-infection on health care utilization and disability: results of the ACTG Longitudinal Linked Randomized Trials (ALLRT) Cohort | J Viral Hepat | Linas, B. P.; Wang, B.; Smurzynski, M.; Losina, E.; Bosch, R. J.; Schackman, B. R.; Rong, J.; Sax, P. E.; Walensky, R. P.; Schouten, J.; Freedberg, K. A. | Not examining outcomes of interest
22937064 | Comparison and temporal trends of three groups with cryptococcosis: HIV-infected, solid organ transplant, and HIV-negative/non-transplant | PLoS One | Bratton, E. W.; El Husseini, N.; Chastain, C. A.; Lee, M. S.; Poole, C.; Sturmer, T.; Juliano, J. J.; Weber, D. J.; Perfect, J. R. | Not examining outcomes of interest
16006210 | Aiming for more relevant HIV risk reduction: a black feminist perspective for enhancing HIV intervention for low-income African American women | AIDS Educ Prev | Gentry, Q. M.; Elifson, K.; Sterk, C. | Not examining outcomes of interest
107911187. Language: | Medication errors in HIV-infected hospitalized patients: a pharmacist's impact | Annals of Pharmacotherapy | Eginger, Kristin H.; Yarborough, Laura L.; Inge, Lisa DeVito; Basile, Sharon A.; Floresca, Donald; Aaronson, Patrick M. | Not examining outcomes of interest
24410324 | Gender moderates the influence of psychosocial factors and drug use on HAART adherence in the context of HIV and childhood sexual abuse | AIDS Care | Wilson, S. M.; Sikkema, K. J.; Ranby, K. W. | Not examining outcomes of interest
23763417 | Substance use among HIV-infected patients engaged in primary care in the United States: findings from the Centers for AIDS Research Network of Integrated Clinical Systems cohort | Am J Public Health | Mimiaga, M. J.; Reisner, S. L.; Grasso, C.; Crane, H. M.; Safren, S. A.; Kitahata, M. M.; Schumacher, J. E.; Mathews, W. C.; Mayer, K. H. | Not examining outcomes of interest
21934446 | Genital warts and vulvar intraepithelial neoplasia: natural history and effects of treatment and human immunodeficiency virus infection | Obstet Gynecol | Massad, L. S.; Xie, X.; Darragh, T.; Minkoff, H.; Levine, A. M.; Watts, D. H.; Wright, R. L.; D'Souza, G.; Colie, C.; Strickler, H. D. | Not examining outcomes of interest
21390537 | Are smokers with HIV using information and communication technology? Implications for behavioral interventions | AIDS Behav | Chander, G.; Stanton, C.; Hutton, H. E.; Abrams, D. B.; Pearson, J.; Knowlton, A.; Latkin, C.; Holtgrave, D.; Moore, R. D.; Niaura, R. | Not examining outcomes of interest
20039804 | Risk of myocardial infarction in patients with HIV infection exposed to specific individual antiretroviral drugs from the 3 major drug classes: the data collection on adverse events of anti-HIV drugs (D:A:D) study | J Infect Dis | Worm, S. W.; Sabin, C.; Weber, R.; Reiss, P.; El-Sadr, W.; Dabis, F.; De Wit, S.; Law, M.; Monforte, A. D.; Friis-Moller, N.; Kirk, O.; Fontas, E.; Weller, I.; Phillips, A.; Lundgren, J. | Not examining outcomes of interest
21135328 | A marginal structural model to estimate the causal effect of antidepressant medication treatment on viral suppression among homeless and marginally housed persons with HIV | Arch Gen Psychiatry | Tsai, A. C.; Weiser, S. D.; Petersen, M. L.; Ragland, K.; Kushel, M. B.; Bangsberg, D. R. | Not examining outcomes of interest
107863130. Language: | The Relationship Between CAM Use and Adherence to Antiretroviral Therapies Among Persons Living With HIV | Health Psychology | Littlewood, Rae A.; Vanable, Peter A. | Not examining outcomes of interest
21286827 | Patterns of exchange sex and HIV infection in high-risk heterosexual men and women | J Urban Health | Jenness, S. M.; Kobrak, P.; Wendel, T.; Neaigus, A.; Murrill, C. S.; Hagan, H. | Not examining outcomes of interest
16758423 | Bacterial pneumonia, HIV therapy, and disease progression among HIV-infected women in the HIV epidemiologic research (HER) study | Clin Infect Dis | Kohli, R.; Lo, Y.; Homel, P.; Flanigan, T. P.; Gardner, L. I.; Howard, A. A.; Rompalo, A. M.; Moskaleva, G.; Schuman, P.; Schoenbaum, E. E. | Not examining outcomes of interest
26215529 | Prevalence of cirrhosis in hepatitis C patients in the Chronic Hepatitis Cohort Study (CHeCS): a retrospective and prospective observational study | Am J Gastroenterol | Gordon, S. C.; Lamerato, L. E.; Rupp, L. B.; Holmberg, S. D.; Moorman, A. C.; Spradling, P. R.; Teshale, E.; Xu, F.; Boscarino, J. A.; Vijayadeva, V.; Schmidt, M. A.; Oja-Tebbe, N.; Lu, M. | Not examining outcomes of interest
23305257 | Co-morbidities in persons infected with HIV: increased burden with older age and negative effects on health-related quality of life | AIDS Patient Care STDS | Rodriguez-Penney, A. T.; Iudicello, J. E.; Riggs, P. K.; Doyle, K.; Ellis, R. J.; Letendre, S. L.; Grant, I.; Woods, S. P. | Not examining outcomes of interest
23892238 | Comparative effectiveness of fish oil versus fenofibrate, gemfibrozil, and atorvastatin on lowering triglyceride levels among HIV-infected patients in routine clinical care | J Acquir Immune Defic Syndr | Munoz, M. A.; Liu, W.; Delaney, J. A.; Brown, E.; Mugavero, M. J.; Mathews, W. C.; Napravnik, S.; Willig, J. H.; Eron, J. J.; Hunt, P. W.; Kahn, J. O.; Saag, M. S.; Kitahata, M. M.; Crane, H. M. | Not examining outcomes of interest
19287303 | Effects of long-term testosterone administration in HIV-infected women: a randomized, placebo-controlled trial | Aids | Dolan Looby, S. E.; Collins, M.; Lee, H.; Grinspoon, S. | Not examining outcomes of interest
21317600 | Improving adherence to HIV quality of care indicators in persons with opioid dependence: the role of buprenorphine | J Acquir Immune Defic Syndr | Korthuis, P. T.; Fiellin, D. A.; Fu, R.; Lum, P. J.; Altice, F. L.; Sohler, N.; Tozzi, M. J.; Asch, S. M.; Botsko, M.; Fishl, M.; Flanigan, T. P.; Boverman, J.; McCarty, D. | Not examining outcomes of interest
17179770 | Reduction in triglyceride level with N-3 polyunsaturated fatty acids in HIV-infected patients taking potent antiretroviral therapy: a randomized prospective study | J Acquir Immune Defic Syndr | De Truchis, P.; Kirstetter, M.; Perier, A.; Meunier, C.; Zucman, D.; Force, G.; Doll, J.; Katlama, C.; Rozenbaum, W.; Masson, H.; Gardette, J.; Melchior, J. C. | Not examining outcomes of interest
17083026 | Risk of cardiovascular disease in a cohort of HIV-infected adults: a study using carotid intima-media thickness and coronary artery calcium score | Clin Infect Dis | Mangili, A.; Gerrior, J.; Tang, A. M.; O'Leary, D. H.; Polak, J. K.; Schaefer, E. J.; Gorbach, S. L.; Wanke, C. A. | Not examining outcomes of interest
25192745 | Simeprevir (TMC435) with pegylated interferon/ribavirin in patients coinfected with HCV genotype 1 and HIV-1: a phase 3 study | Clin Infect Dis | Dieterich, D.; Rockstroh, J. K.; Orkin, C.; Gutierrez, F.; Klein, M. B.; Reynes, J.; Shukla, U.; Jenkins, A.; Lenz, O.; Ouwerkerk-Mahadevan, S.; Peeters, M.; De La Rosa, G.; Tambuyzer, L.; Jessner, W. | Not examining outcomes of interest
25754980 | Structural Bone Deficits in HIV/HCV-Coinfected, HCV-Monoinfected, and HIV-Monoinfected Women | J Infect Dis | Lo Re, V., 3rd; Lynn, K.; Stumm, E. R.; Long, J.; Nezamzadeh, M. S.; Baker, J. F.; Hoofnagle, A. N.; Kapalko, A. J.; Mounzer, K.; Zemel, B. S.; Tebas, P.; Kostman, J. R.; Leonard, M. B. | Not examining outcomes of interest
23795312 | The effects of extended release niacin on lipoprotein sub-particle concentrations in HIV-infected patients | Hawaii J Med Public Health | Lin, C.; Grandinetti, A.; Shikuma, C.; Souza, S.; Parikh, N.; Nakamoto, B.; Kallianpur, K. J.; Chow, D. | Not examining outcomes of interest
17703710 | The relationship between lifetime abuse and suicidal ideation in a sample of injection drug users | J Psychoactive Drugs | Lloyd, J. J.; Ricketts, E. P.; Havens, J. R.; Cornelius, L. J.; Bishai, D.; Huettner, S.; Latkin, C.; Strathdee, S. A. | Not examining outcomes of interest
2014-00386-005 | Aging, antiretrovirals, and adherence: A meta analysis of adherence among older HIV-infected individuals | Drugs & Aging | Ghidei, Luwam; Simone, Mark J.; Salow, Marci J.; Zimmerman, Kristin M.; Paquin, Allison M.; Skarf, Lara M.; Kostas, Tia R. M.; Rudolph, James L. | Not examining outcomes of interest
24457115 | Transient increment of HTLV-2 proviral load in HIV-1-co-infected patients during treatment intensification with raltegravir | J Clin Virol | Abad-Fernandez, M.; Cabrera, C.; Garcia, E.; Vallejo, A. | Not examining outcomes of interest
21220772 | T cell activation and senescence predict subclinical carotid artery disease in HIV-infected women | J Infect Dis | Kaplan, R. C.; Sinclair, E.; Landay, A. L.; Lurain, N.; Sharrett, A. R.; Gange, S. J.; Xue, X.; Hunt, P.; Karim, R.; Kern, D. M.; Hodis, H. N.; Deeks, S. G. | Not examining outcomes of interest
15767199 | Suicide risk and mental health indicators: Do they differ by abuse and HIV status? | Womens Health Issues | Gielen, A. C.; McDonnell, K. A.; O'Campo, P. J.; Burke, J. G. | Not examining outcomes of interest
16716848 | Safety, efficacy, and tolerability of nelfinavir-containing antiretroviral therapy for patients coinfected with HIV and hepatitis C undergoing methadone maintenance | J Subst Abuse Treat | Brown, L. S., Jr.; Kritz, S.; Chu, M.; Madray, C. | Not examining outcomes of interest
23362285 | Early versus delayed antiretroviral therapy and cerebrospinal fluid fungal clearance in adults with HIV and cryptococcal meningitis | Clin Infect Dis | Bisson, G. P.; Molefi, M.; Bellamy, S.; Thakur, R.; Steenhoff, A.; Tamuhla, N.; Rantleru, T.; Tsimako, I.; Gluckman, S.; Ravimohan, S.; Weissman, D.; Tebas, P. | Not examining outcomes of interest
21048934 | IL28B SNP rs8099917 is strongly associated with pegylated interferon-alpha and ribavirin therapy treatment failure in HCV/HIV-1 coinfected patients | PLoS One | Aparicio, E.; Parera, M.; Franco, S.; Perez-Alvarez, N.; Tural, C.; Clotet, B.; Martinez, M. A. | Not examining outcomes of interest
24752996 | Persistent viremia in human immunodeficiency virus/hepatitis B coinfected patients undergoing long-term tenofovir: virological and clinical implications | Hepatology | Boyd, A.; Gozlan, J.; Maylin, S.; Delaugerre, C.; Peytavin, G.; Girard, P. M.; Zoulim, F.; Lacombe, K. | Not examining outcomes of interest
21831304 | Antihyperlipidemic effects of Pleurotus ostreatus (oyster mushrooms) in HIV-infected individuals taking antiretroviral therapy | BMC Complement Altern Med | Abrams, D. I.; Couey, P.; Shade, S. B.; Kelly, M. E.; Kamanu-Elias, N.; Stamets, P. | Not examining outcomes of interest
16313290 | Clinical outcomes of first antiretroviral regimen in HIV/hepatitis C virus co-infection | HIV Med | Cooper, C. L.; Breau, C.; Laroche, A.; Lee, C.; Garber, G. | Not examining outcomes of interest
25403718 | Healthcare costs associated with antiretroviral adherence among medicaid patients | Appl Health Econ Health Policy | Pruitt, Z.; Robst, J.; Langland-Orban, B.; Brooks, R. G. | Not examining outcomes of interest
23806058 | Antiviral regimen complexity index as an independent predictor of sustained virologic response in patients with chronic hepatitis C | J Manag Care Pharm | Galan, R. J.; Cidoncha, E. C.; Martin, M. F.; Rodriguez, C. C.; Almeida, C. V.; Verdugo, R. M. | Not examining outcomes of interest
22643470 | Disparities in HIV-treatment responses between Haitians, African Americans, and Hispanics living in Miami-Dade County, Florida | J Health Care Poor Underserved | Colasanti, J.; Nguyen, L.; Kiem, J. T.; Deeb, K.; Jayaweera, D. | Not examining outcomes of interest
23121723 | Focus on increasing treatment self-efficacy to improve human immunodeficiency virus treatment adherence | J Nurs Scholarsh | Nokes, K.; Johnson, M. O.; Webel, A.; Rose, C. D.; Phillips, J. C.; Sullivan, K.; Tyer-Viola, L.; Rivero-Mendez, M.; Nicholas, P.; Kemppainen, J.; Sefcik, E.; Chen, W. T.; Brion, J.; Eller, L.; Kirksey, K.; Wantland, D.; Portillo, C.; Corless, I. B.; Voss, J.; Iipinge, S.; Spellmann, M.; Holzemer, W. L. | Not examining outcomes of interest
24872131 | Increase in CD4 count among new enrollees in HIV care in the modern antiretroviral therapy era | J Acquir Immune Defic Syndr | Haines, C. F.; Fleishman, J. A.; Yehia, B. R.; Berry, S. A.; Moore, R. D.; Bamford, L. P.; Gebo, K. A. | Not examining outcomes of interest
18338961 | Influence of prior antiretroviral experience on adherence and responses to new highly active antiretroviral therapy regimens | AIDS Patient Care STDS | Horberg, M.; Silverberg, M.; Hurley, L.; Delorenze, G.; Quesenberry, C. | Not examining outcomes of interest
24330207 | Medication adherence feedback intervention predicts improved human immunodeficiency virus clinical markers | Int J Nurs Pract | Reich, W. A. | Not examining outcomes of interest
16044004 | The association of race, sociodemographic, and behavioral characteristics with response to highly active antiretroviral therapy in women | J Acquir Immune Defic Syndr | Anastos, K.; Schneider, M. F.; Gange, S. J.; Minkoff, H.; Greenblatt, R. M.; Feldman, J.; Levine, A.; Delapenha, R.; Cohen, M. | Not examining outcomes of interest
18320045 | Overestimates of survival after HAART: implications for global scale-up efforts | PLoS One | Bisson, G. P.; Gaolathe, T.; Gross, R.; Rollins, C.; Bellamy, S.; Mogorosi, M.; Avalos, A.; Friedman, H.; Dickinson, D.; Frank, I.; Ndwapi, N. | Not examining outcomes of interest
19555288 | Treatment responses in antiretroviral treatment-naive premenopausal and postmenopausal HIV-1-infected women: an analysis from AIDS Clinical Trials Group Studies | Clin Infect Dis | Patterson, K. B.; Cohn, S. E.; Uyanik, J.; Hughes, M.; Smurzynski, M.; Eron, J. J. | Not examining outcomes of interest
15949070 | The adherence to antiretroviral treatment evaluated from a hospital pharmacy: importance of the protease inhibitors pharmacological class | Int J STD AIDS | Rubio, M.; Pedeboscq, S.; Ekouevi, D.; Zalabadi, K.; Chene, G.; Bonarek, M.; Pometan, J. P. | Not examining outcomes of interest
23388678 | Association between risk behaviors and antiretroviral resistance in HIV-infected patients receiving opioid agonist treatment | J Addict Med | Tetrault, J. M.; Kozal, M. J.; Chiarella, J.; Sullivan, L. E.; Dinh, A. T.; Fiellin, D. A. | Not examining outcomes of interest
17505918 | Complementary and alternative medicine use decreases adherence to HAART in HIV-positive women | AIDS Care | Owen-Smith, A.; Diclemente, R.; Wingood, G. | Not examining outcomes of interest
25407085 | HIV and aging: insights from the Asia Pacific HIV Observational Database (APHOD) | HIV Med | Han, N.; Wright, S. T.; O'Connor, C. C.; Hoy, J.; Ponnampalavanar, S.; Grotowski, M.; Zhao, H. X.; Kamarulzaman, A. | Not examining outcomes of interest
22767342 | Patterns of antiretroviral therapy adherence and impact on HIV RNA among patients in North America | Aids | Genberg, B. L.; Wilson, I. B.; Bangsberg, D. R.; Arnsten, J.; Goggin, K.; Remien, R. H.; Simoni, J.; Gross, R.; Reynolds, N.; Rosen, M.; Liu, H. | Not examining outcomes of interest
21297425 | Persistence of HIV-associated cognitive impairment, inflammation, and neuronal injury in era of highly active antiretroviral treatment | Aids | Harezlak, J.; Buchthal, S.; Taylor, M.; Schifitto, G.; Zhong, J.; Daar, E.; Alger, J.; Singer, E.; Campbell, T.; Yiannoutsos, C.; Cohen, R.; Navia, B. | Not examining outcomes of interest
25772053 | Rural-urban differences in HIV viral loads and progression to AIDS among new HIV cases | South Med J | Weissman, S.; Duffus, W. A.; Iyer, M.; Chakraborty, H.; Samantapudi, A. V.; Albrecht, H. | Not examining outcomes of interest
107933738. Language: | Predictors of program attendance for a group based HIV/AIDS self-management program | Communicatin g Nursing Research | Sullivan, K. M.; Inouye, J.; Nigg, C. | Not published (abstract/thesis)
2008-99220-131 | An ethnography study of HIV positive midlife Black women | | Stoudmire, Charlotte | Not published (abstract/thesis)
105209663. Language: | Boredom in recovery for adult substance users with HIV/AIDS attending an urban day treatment program | Occupational Therapy in Mental Health | Corvinelli, A. | Not published (abstract/thesis)
2015-99060-098 | Retention in care among vulnerable hiv-positive populations: The impact of socio-contextual factors | | McDoom-Echebiri, Mahada Maya | Not published (abstract/thesis)
2015-99140-173 | Women's HIV Prevention Study (WHIPS): A proposal to pilot test an HIV intervention for older African American women living with HIV | | Cherry, Charsey | Not published (abstract/thesis)
2013-99140-142 | Factors associated with antiretroviral therapy nonadherence in older adults with HIV | | McCoy, Katryna Floyd | Not published (abstract/thesis)
2007-99017-126 | The effects of group mental health intervention on adherence to medication, for people with hiv and aids | | Freedman, Diane E. | Not published (abstract/thesis)
2005-99010-165 | Impact of HIV/AIDS on health-related quality of life in women fifty and older: A qualitative study | NA | Durham, Doris | Not published (abstract/thesis)
106189023. Language: | Women's choice of strategies for improving utilization of HIV/AIDS screening services | Health Care for Women International | Ikorok, M. M.; Akpabio, , II | Not relevant
18773797 | Domestic violence shelters as prevention agents for HIV/AIDS? | Health Soc Work | Rountree, M. A.; Pomeroy, E. C.; Marsiglia, F. F. | Not relevant
18160376 | The SISTA pilot project: understanding the training and technical assistance needs of community-based organizations implementing HIV prevention interventions for African American women--implications for a capacity building strategy | Women Health | Fuller, T. R.; Brown, M.; King, W.; Prather, C.; Cazaubon, J.; Mack, J.; Russell, B. | Not relevant
107910901. Language: | Human immunodeficiency virus and menopause | Menopause (10723714) | Kanapathipillai, Rupa; Hickey, Martha; Giles, Michelle | Not relevant
23188480 | Videos to influence: a systematic review of effectiveness of video-based education in modifying health behaviors | Journal of Behavioral Medicine | Tuong, William; Larsen, Elizabeth; Armstrong, April | Not relevant
17109360 | Recurrence of symptomatic bacterial vaginosis 12 months after oral metronidazole therapy in HIV-positive and -negative women | Journal of Infectious Diseases | Myer, L.; Kuhn, L.; Denny, L.; Wright, T. C., Jr. | Not relevant
15812617 | Use of electronic monitoring devices to measure antiretroviral adherence: practical considerations | AIDS Behav | Bova, C. A.; Fennie, K. P.; Knafl, G. J.; Dieckhaus, K. D.; Watrous, E.; Williams, A. B. | Not relevant
22267016 | Retention in care of adults and adolescents living with HIV in 13 U.S. areas | J Acquir Immune Defic Syndr | Hall, H. I.; Gray, K. M.; Tang, T.; Li, J.; Shouse, L.; Mermin, J. | Not relevant
20632080 | Predicting adherence to antiretroviral therapy in HIV-infected older adults: the moderating role of gender | AIDS Behav | Bianco, J. A.; Heckman, T. G.; Sutton, M.; Watakakosol, R.; Lovejoy, T. | Not relevant
22930794 | Choosing sides: HIV health care practices among shared populations of HIV-positive Latinos living near the US-Mexico border | J Int Assoc Physicians AIDS Care (Chic) | Servin, A. E.; Munoz, F. A.; Strathdee, S. A.; Kozo, J.; Zuniga, M. L. | Not relevant
16808754 | Is the quality of the patient-provider relationship associated with better adherence and health outcomes for patients with HIV? | J Gen Intern Med | Beach, M. C.; Keruly, J.; Moore, R. D. | Not relevant
24769625 | The potential for elimination of racial-ethnic disparities in HIV treatment initiation in the Medicaid population among 14 southern states | PLoS One | Zhang, S.; McGoy, S. L.; Dawes, D.; Fransua, M.; Rust, G.; Satcher, D. | Not relevant
24037440 | Understanding the revolving door: individual and structural-level predictors of recidivism among individuals with HIV leaving jail | AIDS Behav | Fu, J. J.; Herme, M.; Wickersham, J. A.; Zelenev, A.; Althoff, A.; Zaller, N. D.; Bazazi, A. R.; Avery, A. K.; Porterfield, J.; Jordan, A. O.; Simon-Levine, D.; Lyman, M.; Altice, F. L. | Not relevant
24032625 | HIV medication adherence and HIV symptom severity: the roles of sleep quality and memory | AIDS Patient Care STDS | Babson, K. A.; Heinz, A. J.; Bonn-Miller, M. O. | Not relevant
25211735 | The influence of race and comorbidity on the timely initiation of antiretroviral therapy among older persons living with HIV/AIDS | Am J Public Health | Abara, W. E.; Smith, L.; Zhang, S.; Fairchild, A. J.; Heiman, H. J.; Rust, G. | Not relevant
15764956 | A comparison of the clinical and cost-effectiveness of 3 intervention strategies for AIDS wasting | J Acquir Immune Defic Syndr | Shevitz, A. H.; Wilson, I. B.; McDermott, A. Y.; Spiegelman, D.; Skinner, S. C.; Antonsson, K.; Layne, J. E.; Beaston-Blaakman, A.; Shepard, D. S.; Gorbach, S. L. | Not relevant
18346000 | Disparities in the provision of sexually transmitted disease and pregnancy testing and prophylaxis for sexually assaulted women in Rhode Island emergency departments | J Womens Health (Larchmt) | Merchant, R. C.; Phillips, B. Z.; Delong, A. K.; Mayer, K. H.; Becker, B. M. | Not relevant
17949723 | Mediating roles of medication-taking self-efficacy and depressive symptoms on self-reported medication adherence in persons with HIV: a questionnaire survey | Int J Nurs Stud | Cha, E.; Erlen, J. A.; Kim, K. H.; Sereika, S. M.; Caruthers, D. | Not relevant
17761583 | Black--White Mortality From HIV in the United States Before and After Introduction of Highly Active Antiretroviral Therapy in 1996 | American Journal of Public Health | Levine, Robert S.; Briggs, Nathaniel C.; Kilbourne, Barbara S.; King, William D.; Fry-Johnson, Yvonne; Baltrus, Peter T.; Husaini, Baqar A.; Rust, George S. | Not relevant
2013-99220-330 | Exploration of coping strategies in older, community dwelling, HIV positive individuals in baltimore | | DeGrezia, Mary G. | Not relevant
21492004 | Mastery and Coping Moderate the Negative Effect of Acute and Chronic Stressors on Mental Health-Related Quality of Life in HIV | AIDS Patient Care & STDs | Gibson, Katherine; Rueda, Sergio; Rourke, Sean B.; Bekele, Tsegaye; Gardner, Sandra; Fenta, Haile; Hart,; the Ohtn Cohort Study, Trevor A. | Not relevant
19472058 | Simultaneous recruitment of drug users and men who have sex with men in the United States and Russia using respondent-driven sampling: sampling methods and implications | J Urban Health | Iguchi, M. Y.; Ober, A. J.; Berry, S. H.; Fain, T.; Heckathorn, D. D.; Gorbach, P. M.; Heimer, R.; Kozlov, A.; Ouellet, L. J.; Shoptaw, S.; Zule, W. A. | Not relevant
15718323 | Profile of patients with Kaposi's sarcoma in the era of highly active antiretroviral therapy | J Clin Oncol | Gallafent, J. H.; Buskin, S. E.; De Turk, P. B.; Aboulafia, D. M. | Not relevant
22872432 | Norms, attitudes, and sex behaviors among women with incarcerated main partners | J Urban Health | Davey-Rothwell, M. A.; Villarroel, M. A.; Grieb, S. D.; Latkin, C. A. | Not relevant
24746376 | Smoking cessation and recidivism in the Women's Interagency Human Immunodeficiency Virus Study | Am J Prev Med | Hessol, N. A.; Weber, K. M.; D'Souza, G.; Burton, D.; Young, M.; Milam, J.; Murchison, L.; Gandhi, M.; Cohen, M. H. | Not relevant
17053854 | Safe syringe disposal is related to safe syringe access among HIV-positive injection drug users | AIDS Behav | Coffin, P. O.; Latka, M. H.; Latkin, C.; Wu, Y.; Purcell, D. W.; Metsch, L.; Gomez, C.; Gourevitch, M. N. | Not relevant
24654969 | Assessing the overall quality of health care in persons living with HIV in an urban environment | AIDS Patient Care STDS | Keller, S. C.; Yehia, B. R.; Momplaisir, F. O.; Eberhart, M. G.; Share, A.; Brady, K. A. | Not relevant
20215618 | Clinical implications of stigma in HIV/AIDS and other sexually transmitted infections | Int J STD AIDS | Neal, T. M.; Lichtenstein, B.; Brodsky, S. L. | Not relevant
18176324 | Consistency of initial antiretroviral therapy with HIV treatment guidelines in a US cohort of HIV-infected women | J Acquir Immune Defic Syndr | Cocohoba, J.; Wang, Q. J.; Cox, C.; Gange, S. J.; Cohen, M.; Glesby, M.; DeHovitz, J. A.; Greenblatt, R. M. | Not relevant
20154577 | Factors associated with delayed entry into primary HIV medical care after HIV diagnosis | Aids | Bamford, L. P.; Ehrenkranz, P. D.; Eberhart, M. G.; Shpaner, M.; Brady, K. A. | Not relevant
18021029 | HIV-positive smokers considering quitting: differences by race/ethnicity | Am J Health Behav | Lloyd-Richardson, E. E.; Stanton, C. A.; Papandonatos, G. D.; Betancourt, R. M.; Stein, M.; Tashima, K.; Morrow, K.; Niaura, R. | Not relevant
19128494 | Inpatient charges among HIV/AIDS patients in Rhode Island from 2000-2004 | BMC Health Serv Res | Barbour, K. E.; Fabio, A.; Pearlman, D. N. | Not relevant
24602364 | Interest in quitting and lifetime quit attempts among smokers living with HIV infection | Drug Alcohol Depend | Pacek, L. R.; Latkin, C.; Crum, R. M.; Stuart, E. A.; Knowlton, A. R. | Not relevant
23011397 | Measuring retention in HIV care: the elusive gold standard | J Acquir Immune Defic Syndr | Mugavero, M. J.; Westfall, A. O.; Zinski, A.; Davila, J.; Drainoni, M. L.; Gardner, L. I.; Keruly, J. C.; Malitz, F.; Marks, G.; Metsch, L.; Wilson, T. E.; Giordano, T. P. | Not relevant
110568088. Language: | Medication-Taking Practices of Patients on Antiretroviral HIV Therapy: Control, Power, and Intentionality | AIDS Patient Care & STDs | | Not relevant
24502460 | Predictors of medication adherence among HIV-positive women in North America | J Obstet Gynecol Neonatal Nurs | Tyer-Viola, L. A.; Corless, I. B.; Webel, A.; Reid, P.; Sullivan, K. M.; Nichols, P. | Not relevant
20220123 | Reciprocal prediction of medication adherence and neurocognition in HIV/AIDS | Neurology | Ettenhofer, M. L.; Foley, J.; Castellon, S. A.; Hinkin, C. H. | Not relevant
20668976 | Self-reevaluation as a critical component in sustained viral load change for HIV+ adults with alcohol problems | Ann Behav Med | Longmire-Avital, B.; Golub, S. A.; Parsons, J. T. | Not relevant
26180958 | Sex-Related Disparities in Criminal Justice and HIV Treatment Outcomes: A Retrospective Cohort Study of HIV-Infected Inmates | Am J Public Health | Meyer, J. P.; Cepeda, J.; Taxman, F. S.; Altice, F. L. | Not relevant
17919094 | Social support, coping, and medication adherence among HIV-positive women with depression living in rural areas of the southeastern United States | AIDS Patient Care STDS | Vyavaharkar, M.; Moneyham, L.; Tavakoli, A.; Phillips, K. D.; Murdaugh, C.; Jackson, K.; Meding, G. | Not relevant
18089265 | The association between body image and smoking cessation among individuals living with HIV/AIDS | Body Image | Fingeret, M. C.; Vidrine, D. J.; Arduino, R. C.; Gritz, E. R. | Not relevant
19454401 | The influence of different types of alcoholic beverages on disrupting highly active antiretroviral treatment (HAART) outcome | Alcohol Alcohol | Miguez-Burbano, M. J.; Lewis, J. E.; Fishman, J.; Asthana, D.; Malow, R. M. | Not relevant
17588200 | The role of self-efficacy in HIV treatment adherence: validation of the HIV Treatment Adherence Self-Efficacy Scale (HIV-ASES) | J Behav Med | Johnson, M. O.; Neilands, T. B.; Dilworth, S. E.; Morin, S. F.; Remien, R. H.; Chesney, M. A. | Not relevant
106463262. Language: | HIV-related stigma among persons attending an urban HIV clinic | Journal of Multicultural Nursing & Health (JMCNH) | Relf, M. V.; Mallinson, K.; Pawlowski, L.; Dolan, K.; Dekker, D. | Not relevant
20821903 | Summary health statistics for U.S. adults: National Health Interview Survey, 2008 | Vital Health Stat 10 | Pleis, J. R.; Lucas, J. W.; Ward, B. W. | Not relevant
22834228 | Summary health statistics for U.S. adults: National Health Interview Survey, 2010 | Vital Health Stat 10 | Schiller, J. S.; Lucas, J. W.; Ward, B. W.; Peregoy, J. A. | Not relevant
24326608 | Discontinuation of antiretroviral therapy among adults receiving HIV care in the United States | J Acquir Immune Defic Syndr | Hughes, A. J.; Mattson, C. L.; Scheer, S.; Beer, L.; Skarbinski, J. | Not relevant
24326606 | Increase in single-tablet regimen use and associated improvements in adherence-related outcomes in HIV-infected women | J Acquir Immune Defic Syndr | Hanna, D. B.; Hessol, N. A.; Golub, E. T.; Cocohoba, J. M.; Cohen, M. H.; Levine, A. M.; Wilson, T. E.; Young, M.; Anastos, K.; Kaplan, R. C. | Not relevant
17806060 | Pillbox organizers are associated with improved adherence to HIV antiretroviral therapy and viral suppression: a marginal structural model analysis | Clin Infect Dis | Petersen, M. L.; Wang, Y.; van der Laan, M. J.; Guzman, D.; Riley, E.; Bangsberg, D. R. | Not relevant
16176890 | Adherence to combined Lamivudine + Zidovudine versus individual components: a community-based retrospective medicaid claims analysis | AIDS Care | Legorreta, A.; Yu, A.; Chernicoff, H.; Gilmore, A.; Jordan, J.; Rosenzweig, J. C. | Not relevant
21507924 | Atazanavir concentration in hair is the strongest predictor of outcomes on antiretroviral therapy | Clin Infect Dis | Gandhi, M.; Ameli, N.; Bacchetti, P.; Anastos, K.; Gange, S. J.; Minkoff, H.; Young, M.; Milam, J.; Cohen, M. H.; Sharp, G. B.; Huang, Y.; Greenblatt, R. M. | Not relevant
104030036. Language: | Antimicrobial Stewardship Program to Reduce Antiretroviral Medication Errors in Hospitalized Patients with Human Immunodeficiency Virus Infection | Infection Control & Hospital Epidemiology | Sanders, Jamie; Pallotta, Andrea; Bauer, Seth; Sekeres, Jennifer; Davis, Ramona; Taege, Alan; Neuner, Elizabeth | Not relevant
104555466. Language: | Development of Evidence-Based Exercise Recommendations for Older HIV-Infected Patients | JANAC: Journal of the Association of Nurses in AIDS Care | Yahiaoui, Anella | Not relevant
24385651 | Data harmonization process for creating the National Center for HIV/AIDS, Viral Hepatitis, STD, and TB Prevention Atlas | Public Health Rep | Elmore, K.; Nelson, R.; Gant, Z.; Jeffries, C.; Broeker, L.; Mirabito, M.; Roberts, H. | Not relevant
2013-99200-183 | HIV/AIDS knowledge, attitudes, condom use self-efficacy, and sexual risk behavior among older Haitian Americans | | Beauvil, Victor | Not relevant
106392781. Language: | Symptom status, medication adherence, and quality of life in HIV disease | Journal of Hospice & Palliative Nursing | Corless, I. B. | Not relevant
2015-99080-293 | Gender power and hiv-related sexual risk behavior in older african american women | | Smith, Tanyka K. | Not relevant
2014-99220-496 | Stigma and quality of life in african american women living with hiv infection through the lens of intersectionality | | Kaihura, Alphoncina John | Not relevant
17434845 | Pilot study of a novel short-cycle antiretroviral treatment interruption strategy: 48-week results of the five-days-on, two-days-off (FOTO) study | HIV Clin Trials | Cohen, C. J.; Colson, A. E.; Sheble-Hall, A. G.; McLaughlin, K. A.; Morse, G. D. | Not relevant
18547903 | Randomization to once-daily stavudine extended release/lamivudine/efavirenz versus a more frequent regimen improves adherence while maintaining viral suppression | HIV Clin Trials | Boyle, B. A.; Jayaweera, D.; Witt, M. D.; Grimm, K.; Maa, J. F.; Seekins, D. W. | Not relevant
18547905 | Virologic success in an urban HIV clinic: outcome at 12 months in patients who were HAART naive | HIV Clin Trials | Blanchard, E.; Klibanov, O. M.; Axelrod, P.; Palermo, B.; Samuel, R. | Not relevant
18753116 | Evaluation of efficacy, safety, pharmacokinetics, and adherence in HIV-1-infected, antiretroviral-naive patients treated with ritonavir-boosted atazanavir plus fixed-dose tenofovir DF/emtricitabine given once daily | HIV Clin Trials | Elion, R.; Cohen, C.; Ward, D.; Ruane, P.; Ortiz, R.; Reddy, Y. S.; Ebrahimi, R.; McColl, D.; Kearney, B.; Fisher, A.; Flaherty, J. | Not relevant
19430094 | Risk factors for loss of virological suppression in patients receiving lopinavir/ritonavir monotherapy for maintenance of HIV suppression | Antivir Ther | Pulido, F.; Perez-Valero, I.; Delgado, R.; Arranz, A.; Pasquau, J.; Portilla, J.; Rubio, R.; Gonzalez-Garcia, J.; Miralles, P.; Perez-Elias, M. J.; Ocampo, A.; Hernando, A.; Estrada, V.; Clotet, B.; Podzamczer, D.; Arribas, J. R. | Not relevant
20677050 | The challenges of seeking and receiving support for women living with HIV | Health Commun | Peterson, J. L. | Not relevant
21631425 | Long-term Medication Adherence in Patients Receiving Antiretroviral Drug Therapy | Curr HIV Res | Preininger, L.; Cantwell-McNelis, K.; James, C.; Sullivan, M. C.; Szabo, S.; Bincsik, A. | Not relevant
22970926 | Adherence and persistence with non-nucleoside reverse transcriptase inhibitor-based antiretroviral regimens | Expert Opin Pharmacother | Taneja, C.; Juday, T.; Gertzog, L.; Edelsberg, J.; Correll, T.; Hebden, T.; Oster, G. | Not relevant
24518212 | Durability of the first antiretroviral treatment regimen and reasons for change in patients with HIV infection | HIV Clin Trials | De La Torre-Lima, J.; Aguilar, A.; Santos, J.; Jimenez-Onate, F.; Marcos, M.; Nunez, V.; Olalla, J.; Del Arco, A.; Prada, J. L. | Not relevant
25062078 | Concurrent use of comedications reduces adherence to antiretroviral therapy among HIV-infected patients | J Manag Care Spec Pharm | Cantudo-Cuenca, M. R.; Jimenez-Galan, R.; Almeida-Gonzalez, C. V.; Morillo-Verdugo, R. | Not relevant
26356739 | Late HIV Testing in a Cohort of HIV-Infected Patients in Puerto Rico | P R Health Sci J | Tossas-Milligan, K. Y.; Hunter-Mellado, R. F.; Mayor, A. M.; Fernandez-Santos, D. M.; Dworkin, M. S. | Not relevant
103968430. Language: | CLINICAL. Comparison Between Guideline-Preferred and Nonpreferred First-Line HIV Antiretroviral Therapy | American Journal of Managed Care | Johnston, Stephen S.; Juday, Timothy; Farr, Amanda M.; Bong-Chul, Chu; Hebden, Tony | Not relevant
104040364. Language: | A Five-Step Process for Interactive Parentâ€“Adolescent Communication About HIV Prevention: Advice From Parents Living With HIV/AIDS | Journal of HIV/AIDS & Social Services | Edwards, Laura L.; Reis, Janet S. | Not relevant
105775699. Language: | Bridging research to practice. Psychosocial factors associated with disclosure of HIV positive serostatus: understanding the influence of depression and social support | Journal of HIV/AIDS & Social Services | Gore-Felton, C.; Power, R.; DurÃ¡n, R.; Sarlati, S.; Palmer, L.; Koopman, C.; Israelski, D.; Porter, J.; Spiegel, D. | Not relevant
103765863. Language: | History of Traumatic Events in HIV-Positive Individuals: Risk Behavior Implications in an Urban Clinic Setting | Journal of HIV/AIDS & Social Services | Raja, Sheela; Holland, Christine; Du Bois, Steve N.; McKirnan, David; Allgood, Kristi L.; Glick, Nancy | Not relevant
16315378 | A comparison of the sociodemographic, risk-behavior, and substance-abuse profile of young vs older HIV-infected Puerto Rican patients | Ethn Dis | Fernandez, D. M.; Gomez Mde, L.; Figueroa, W.; Velazquez, M.; Baez, D. V.; Rios-Olivares, E.; Hunter, R. F. | Not relevant
19007720 | Down low sex, older African American women, and HIV infection | JANAC: Journal of the Association of Nurses in AIDS Care | Whyte, James; Whyte, Maria D.; Cormier, Eileen | Not relevant
16831787 | The role of family caregivers in HIV medication adherence | AIDS Care | Beals, K. P.; Wight, R. G.; Aneshensel, C. S.; Murphy, D. A.; Miller-Martinez, D. | Not relevant
25211596 | A forgotten population: older adults with newly diagnosed HIV | AIDS Patient Care STDS | Ellman, T. M.; Sexton, M. E.; Warshafsky, D.; Sobieszczyk, M. E.; Morrison, E. A. | Not relevant
19386970 | A novel use of AIDS surveillance data to assess the impact of initial treatment regimen on survival | Int J STD AIDS | Chen, S. Y.; Moss, W. J.; Pipkin, S. S.; McFarland, W. | Not relevant
21104007 | A post-trial assessment of factors influencing study drug adherence in a randomized biomedical HIV-1 prevention trial | AIDS Behav | Jacob, S. T.; Baeten, J. M.; Hughes, J. P.; Peinado, J.; Wang, J.; Sanchez, J.; Reid, S. E.; Delany-Moretlwe, S.; Cowan, F.; Fuchs, J. D.; Koblin, B.; Griffith, S.; Wald, A.; Celum, C. | Not relevant
16719607 | A Social Problem-Solving Model of Adherence to HIV Medications | Health Psychol | Johnson, M. O.; Elliott, T. R.; Neilands, T. B.; Morin, S. F.; Chesney, M. A. | Not relevant
18260802 | A ten-year analysis of the incidence and risk factors for acute pancreatitis requiring hospitalization in an urban HIV clinical cohort | AIDS Patient Care STDS | Riedel, D. J.; Gebo, K. A.; Moore, R. D.; Lucas, G. M. | Not relevant
22384040 | Adherence to antiretroviral treatment and correlation with risk of hospitalization among commercially insured HIV patients in the United States | PLoS One | Sax, P. E.; Meyers, J. L.; Mugavero, M.; Davis, K. L. | Not relevant
18482946 | AIDS stigma among inmates and staff in a USA state prison | Int J STD AIDS | Derlega, V. J.; Winstead, B. A.; Brockington, J. E., Jr. | Not relevant
22579434 | An investigation of the possible interaction between the use of Vitamin C and highly active antiretroviral therapy (HAART) adherence and effectiveness in treated HIV+ women | Complement Ther Med | Merenstein, D.; Wang, C.; Gandhi, M.; Robison, E.; Levine, A. M.; Schwartz, R. M.; Weber, K. M.; Liu, C. | Not relevant
19542863 | Association of abacavir and impaired endothelial function in treated and suppressed HIV-infected patients | Aids | Hsue, P. Y.; Hunt, P. W.; Wu, Y.; Schnell, A.; Ho, J. E.; Hatano, H.; Xie, Y.; Martin, J. N.; Ganz, P.; Deeks, S. G. | Not relevant
19910347 | Association of race, substance abuse, and health insurance coverage with use of highly active antiretroviral therapy among HIV-infected women, 2005 | Am J Public Health | Lillie-Blanton, M.; Stone, V. E.; Snow Jones, A.; Levi, J.; Golub, E. T.; Cohen, M. H.; Hessol, N. A.; Wilson, T. E. | Not relevant
17693895 | Associations between recent gender-based violence and pregnancy, sexually transmitted infections, condom use practices, and negotiation of sexual practices among HIV-positive women | J Acquir Immune Defic Syndr | Lang, D. L.; Salazar, L. F.; Wingood, G. M.; DiClemente, R. J.; Mikhail, I. | Not relevant
22994586 | Cardiovascular risk factors and carotid intima-media thickness are associated with lower cognitive performance in HIV-infected patients | HIV Med | Fabbiani, M.; Ciccarelli, N.; Tana, M.; Farina, S.; Baldonero, E.; Di Cristo, V.; Colafigli, M.; Tamburrini, E.; Cauda, R.; Silveri, M. C.; Grima, P.; Di Giambenedetto, S. | Not relevant
25369333 | CD161+ MAIT cells are severely reduced in peripheral blood and lymph nodes of HIV-infected individuals independently of disease progression | PLoS One | Eberhard, J. M.; Hartjen, P.; Kummer, S.; Schmidt, R. E.; Bockhorn, M.; Lehmann, C.; Balagopal, A.; Hauber, J.; van Lunzen, J.; Schulze zur Wiesch, J. | Not relevant
18095838 | Concurrent HIV/AIDS diagnosis increases the risk of short-term HIV-related death among persons newly diagnosed with AIDS, 2002-2005 | AIDS Patient Care STDS | Hanna, D. B.; Pfeiffer, M. R.; Torian, L. V.; Sackoff, J. E. | Not relevant
24646419 | Correlates of antiretroviral adherence and viral load among transgender women living with HIV | AIDS Care | Sevelius, J. M.; Saberi, P.; Johnson, M. O. | Not relevant
24093715 | Depressive symptoms, self-esteem, HIV symptom management self-efficacy and self-compassion in people living with HIV | AIDS Care | Eller, L. S.; Rivero-Mendez, M.; Voss, J.; Chen, W. T.; Chaiphibalsarisdi, P.; Iipinge, S.; Johnson, M. O.; Portillo, C. J.; Corless, I. B.; Sullivan, K.; Tyer-Viola, L.; Kemppainen, J.; Rose, C. D.; Sefcik, E.; Nokes, K.; Phillips, J. C.; Kirksey, K.; Nicholas, P. K.; Wantland, D.; Holzemer, W. L.; Webel, A. R.; Brion, J. M. | Not relevant
21973307 | Depressive symptoms, substance use, and HIV-related high-risk behaviors among opioid-dependent individuals: results from the Clinical Trials Network | Subst Use Misuse | Pilowsky, D. J.; Wu, L. T.; Burchett, B.; Blazer, D. G.; Ling, W. | Not relevant
19015925 | Disparities in reported reasons for not initiating or stopping antiretroviral treatment among a diverse sample of persons living with HIV | J Gen Intern Med | Johnson, M. O.; Chesney, M. A.; Neilands, T. B.; Dilworth, S. E.; Remien, R. H.; Weinhardt, L. S.; Wong, F. L.; Morin, S. F. | Not relevant
17697855 | Does distress tolerance moderate the impact of major life events on psychosocial variables and behaviors important in the management of HIV? | Behav Ther | O'Cleirigh, C.; Ironson, G.; Smits, J. A. | Not relevant
24415784 | Effect of 24 weeks of statin therapy on systemic and vascular inflammation in HIV-infected subjects receiving antiretroviral therapy | J Infect Dis | Eckard, A. R.; Jiang, Y.; Debanne, S. M.; Funderburg, N. T.; McComsey, G. A. | Not relevant
18058416 | Factors associated with altered pharmacokinetics in substance users and non-substance users receiving lopinavir and atazanavir | Am J Addict | Higgins, N.; Zingman, B. S.; Slish, J.; Reichman, R. C.; Fischl, M. A.; Gripshover, B.; Tooley, K.; Boston, N.; Forrest, A.; Brazeau, D.; Catanzaro, L. M.; DiFrancesco, R.; Lliguicota, F.; Ma, Q.; Morse, G. D. | Not relevant
21380494 | Factors associated with quality of life among rural women with HIV disease | AIDS Behav | Vyavaharkar, M.; Moneyham, L.; Murdaugh, C.; Tavakoli, A. | Not relevant
19644748 | Food insecurity among homeless and marginally housed individuals living with HIV/AIDS in San Francisco | AIDS Behav | Weiser, S. D.; Bangsberg, D. R.; Kegeles, S.; Ragland, K.; Kushel, M. B.; Frongillo, E. A. | Not relevant
22293432 | Genetic diversity of recently acquired and prevalent HIV, hepatitis B virus, and hepatitis C virus infections in US blood donors | J Infect Dis | Delwart, E.; Slikas, E.; Stramer, S. L.; Kamel, H.; Kessler, D.; Krysztof, D.; Tobler, L. H.; Carrick, D. M.; Steele, W.; Todd, D.; Wright, D. J.; Kleinman, S. H.; Busch, M. P. | Not relevant
24755434 | Gut epithelial barrier dysfunction and innate immune activation predict mortality in treated HIV infection | J Infect Dis | Hunt, P. W.; Sinclair, E.; Rodriguez, B.; Shive, C.; Clagett, B.; Funderburg, N.; Robinson, J.; Huang, Y.; Epling, L.; Martin, J. N.; Deeks, S. G.; Meinert, C. L.; Van Natta, M. L.; Jabs, D. A.; Lederman, M. M. | Not relevant
20419478 | Health and treatment implications of food insufficiency among people living with HIV/AIDS, Atlanta, Georgia | J Urban Health | Kalichman, S. C.; Cherry, C.; Amaral, C.; White, D.; Kalichman, M. O.; Pope, H.; Swetsze, C.; Jones, M.; Macy, R. | Not relevant
21446785 | Health needs of HIV-infected women in the United States: insights from the women living positive survey | AIDS Patient Care STDS | Squires, K. E.; Hodder, S. L.; Feinberg, J.; Bridge, D. A.; Abrams, S.; Storfer, S. P.; Aberg, J. A. | Not relevant
19617816 | HIV patients with psychiatric disorders are less likely to discontinue HAART | Aids | Himelhoch, S.; Brown, C. H.; Walkup, J.; Chander, G.; Korthius, P. T.; Afful, J.; Gebo, K. A. | Not relevant
21779954 | HIV risk behaviors of male and female jail inmates prior to incarceration and one year post-release | AIDS Behav | Adams, L. M.; Kendall, S.; Smith, A.; Quigley, E.; Stuewig, J. B.; Tangney, J. P. | Not relevant
17460469 | HIV-infected patients receiving lopinavir/ritonavir-based antiretroviral therapy achieve high rates of virologic suppression despite adherence rates less than 95% | J Acquir Immune Defic Syndr | Shuter, J.; Sarlo, J. A.; Kanmaz, T. J.; Rode, R. A.; Zingman, B. S. | Not relevant
18243580 | HIV-positive patients' discussion of alcohol use with their HIV primary care providers | Drug Alcohol Depend | Metsch, L. R.; Pereyra, M.; Colfax, G.; Dawson-Rose, C.; Cardenas, G.; McKirnan, D.; Eroglu, D. | Not relevant
22694717 | HIV, aging, and advance care planning: are we successfully planning for the future? | J Palliat Med | Erlandson, K. M.; Allshouse, A. A.; Duong, S.; MaWhinney, S.; Kohrt, W. M.; Campbell, T. B. | Not relevant
16433106 | HIV/AIDS patient satisfaction with hospitalization in the era of highly active antiretroviral therapy | J Assoc Nurses AIDS Care | Wolosin, R. J. | Not relevant
25512624 | Hospitalization Rates and Reasons Among HIV Elite Controllers and Persons With Medically Controlled HIV Infection | J Infect Dis | Crowell, T. A.; Gebo, K. A.; Blankson, J. N.; Korthuis, P. T.; Yehia, B. R.; Rutstein, R. M.; Moore, R. D.; Sharp, V.; Nijhawan, A. E.; Mathews, W. C.; Hanau, L. H.; Corales, R. B.; Beil, R.; Somboonwit, C.; Edelstein, H.; Allen, S. L.; Berry, S. A. | Not relevant
24630627 | I should know better': the roles of relationships, spirituality, disclosure, stigma, and shame for older women living with HIV seeking support in the South | J Assoc Nurses AIDS Care | Grodensky, C. A.; Golin, C. E.; Jones, C.; Mamo, M.; Dennis, A. C.; Abernethy, M. G.; Patterson, K. B. | Not relevant
19537953 | Impact of cigarette smoking on mortality in HIV-positive and HIV-negative veterans | AIDS Educ Prev | Crothers, K.; Goulet, J. L.; Rodriguez-Barradas, M. C.; Gibert, C. L.; Oursler, K. A.; Goetz, M. B.; Crystal, S.; Leaf, D. A.; Butt, A. A.; Braithwaite, R. S.; Peck, R.; Justice, A. C. | Not relevant
24473489 | Incidence of transmitted antiretroviral drug resistance in treatment-naive HIV-1-infected persons in a large South Central United States clinic | Ann Pharmacother | Kleyn, T. J.; Liedtke, M. D.; Harrison, D. L.; Lockhart, S. M.; Salvaggio, M. R.; Ripley, T. L.; Rathbun, R. C. | Not relevant
20104122 | Incident depression symptoms are associated with poorer HAART adherence: a longitudinal analysis from the Nutrition for Healthy Living study | J Acquir Immune Defic Syndr | Kacanek, D.; Jacobson, D. L.; Spiegelman, D.; Wanke, C.; Isaac, R.; Wilson, I. B. | Not relevant
16686082 | Initial testing of the Antiretroviral Medication Complexity Index | J Assoc Nurses AIDS Care | DiIorio, C.; McDonnell, M.; McCarty, F.; Yeager, K. | Not relevant
22612519 | Intimate partner violence: a predictor of worse HIV outcomes and engagement in care | AIDS Patient Care STDS | Schafer, K. R.; Brant, J.; Gupta, S.; Thorpe, J.; Winstead-Derlega, C.; Pinkerton, R.; Laughon, K.; Ingersoll, K.; Dillingham, R. | Not relevant
15798384 | Knowledge of structured treatment interruption and adherence to antiretroviral therapy | AIDS Patient Care STDS | Acri, T.; Coco, A.; Lin, K.; Johnson, R.; Eckert, P. | Not relevant
19487952 | Liver stiffness as a predictor of esophageal varices requiring therapy in HIV/hepatitis C virus-coinfected patients with cirrhosis | J Acquir Immune Defic Syndr | Pineda, J. A.; Recio, E.; Camacho, A.; Macias, J.; Almodovar, C.; Gonzalez-Serrano, M.; Merino, D.; Tellez, F.; Rios, M. J.; Rivero, A. | Not relevant
19519230 | Low levels of adherence to antiretroviral therapy in HIV-1-infected women with menstrual disorders | AIDS Patient Care STDS | Fumaz, C. R.; Munoz-Moreno, J. A.; Ferrer, M. J.; Negredo, E.; Perez-Alvarez, N.; Tarrats, A.; Clotet, B. | Not relevant
25344521 | Lymphoid fibrosis occurs in long-term nonprogressors and persists with antiretroviral therapy but may be reversible with curative interventions | J Infect Dis | Sanchez, J. L.; Hunt, P. W.; Reilly, C. S.; Hatano, H.; Beilman, G. J.; Khoruts, A.; Jasurda, J. S.; Somsouk, M.; Thorkelson, A.; Russ, S.; Anderson, J.; Deeks, S. G.; Schacker, T. W. | Not relevant
25139003 | Magnetic resonance imaging evaluation of lipodystrophy in HIV-positive patients receiving highly active antiretroviral therapy | Int J STD AIDS | Eichler, K. | Not relevant
15608523 | Marijuana use and its association with adherence to antiretroviral therapy among HIV-infected persons with moderate to severe nausea | J Acquir Immune Defic Syndr | de Jong, B. C.; Prentiss, D.; McFarland, W.; Machekano, R.; Israelski, D. M. | Not relevant
25856875 | Measuring health literacy among people living with HIV who attend a community-based ambulatory clinic in Puerto Rico | P R Health Sci J | | Not relevant
16304456 | Medicare part D and antiretroviral therapy: issues for HIV clinicians | Top HIV Med | Cheever, L. W.; Vienna, M. R. | Not relevant
25027465 | Monitoring retention in care: using multiple laboratory tests as an indicator for HIV medical care | AIDS Care | Firth, C. L.; Schafer, S. D.; Greene, K. | Not relevant
20579905 | Multi-dimensional risk factor patterns associated with non-use of highly active antiretroviral therapy among human immunodeficiency virus-infected women | Womens Health Issues | Jones, A. S.; Lillie-Blanton, M.; Stone, V. E.; Ip, E. H.; Zhang, Q.; Wilson, T. E.; Cohen, M. H.; Golub, E. T.; Hessol, N. A. | Not relevant
21950530 | National estimates of the characteristics of individuals infected with HIV who are likely to report and receive treatment for painful bleeding gums | Spec Care Dentist | Sy, A. A.; Freed, B. A.; Chau, F. K.; Marcus, M. | Not relevant
18754703 | Networks of older New Yorkers with HIV: fragility, resilience, and transformation | AIDS Patient Care STDS | Poindexter, C.; Shippy, R. A. | Not relevant
21391011 | Normative data and validation of a regression based summary score for assessing meaningful neuropsychological change | J Clin Exp Neuropsychol | Cysique, L. A.; Franklin, D., Jr.; Abramson, I.; Ellis, R. J.; Letendre, S.; Collier, A.; Clifford, D.; Gelman, B.; McArthur, J.; Morgello, S.; Simpson, D.; McCutchan, J. A.; Grant, I.; Heaton, R. K. | Not relevant
22775237 | Operationalizing treatment as prevention in Los Angeles County: antiretroviral therapy use and factors associated with unsuppressed viral load in the Ryan White system of care | AIDS Patient Care STDS | Sayles, J. N.; Rurangirwa, J.; Kim, M.; Kinsler, J.; Oruga, R.; Janson, M. | Not relevant
19875634 | Overload: impact of incident stressful events on antiretroviral medication adherence and virologic failure in a longitudinal, multisite human immunodeficiency virus cohort study | Psychosom Med | Mugavero, M. J.; Raper, J. L.; Reif, S.; Whetten, K.; Leserman, J.; Thielman, N. M.; Pence, B. W. | Not relevant
24984142 | Pain treatment and antiretroviral medication adherence among vulnerable HIV-positive patients | AIDS Patient Care STDS | Surratt, H. L.; Kurtz, S. P.; Levi-Minzi, M. A.; Cicero, T. J.; Tsuyuki, K.; O'Grady, C. L. | Not relevant
23995296 | Parks as a tool for HIV management | J Int Assoc Provid AIDS Care | Shacham, E.; Hipp, J. A.; Scheuermann, M.; Onen, N.; Overton, E. T. | Not relevant
16310615 | Patient reports of symptoms and their treatment at three palliative care projects servicing individuals with HIV/AIDS | J Pain Symptom Manage | Karus, D.; Raveis, V. H.; Alexander, C.; Hanna, B.; Selwyn, P.; Marconi, K.; Higginson, I. | Not relevant
24099510 | Perspectives of middle-aged African-American women in the Deep South on antiretroviral therapy adherence | AIDS Care | DeMoss, M.; Bonney, L.; Grant, J.; Klein, R.; del Rio, C.; Barker, J. C. | Not relevant
23907506 | Poly-tobacco use among HIV-positive smokers: implications for smoking cessation efforts | Nicotine Tob Res | Tami-Maury, I.; Vidrine, D. J.; Fletcher, F. E.; Danysh, H.; Arduino, R.; Gritz, E. R. | Not relevant
17109679 | Pretreatment assessment and predictors of hepatitis C virus treatment in US veterans coinfected with HIV and hepatitis C virus | J Viral Hepat | Backus, L. I.; Boothroyd, D. B.; Phillips, B. R.; Mole, L. A. | Not relevant
23307396 | Primary care provider cultural competence and racial disparities in HIV care and outcomes | J Gen Intern Med | Saha, S.; Korthuis, P. T.; Cohn, J. A.; Sharp, V. L.; Moore, R. D.; Beach, M. C. | Not relevant
23391684 | Problems and processes in medical encounters: the cases method of dialogue analysis | Patient Educ Couns | Laws, M. B.; Taubin, T.; Bezreh, T.; Lee, Y.; Beach, M. C.; Wilson, I. B. | Not relevant
22426597 | Recent trauma is associated with antiretroviral failure and HIV transmission risk behavior among HIV-positive women and female-identified transgenders | AIDS Behav | Machtinger, E. L.; Haberer, J. E.; Wilson, T. C.; Weiss, D. S. | Not relevant
21556960 | Regional areas and widths of the midsagittal corpus callosum among HIV-infected patients on stable antiretroviral therapies | J Neurovirol | Tate, D. F.; Sampat, M.; Harezlak, J.; Fiecas, M.; Hogan, J.; Dewey, J.; McCaffrey, D.; Branson, D.; Russell, T.; Conley, J.; Taylor, M.; Schifitto, G.; Zhong, J.; Daar, E. S.; Alger, J.; Brown, M.; Singer, E.; Campbell, T.; McMahon, D.; Tso, Y.; Matesan, J.; Letendre, S.; Paulose, S.; Gaugh, M.; Tripoli, C.; Yiannoutsos, C.; Bigler, E. D.; Cohen, R. A.; Guttmann, C. R.; Navia, B. | Not relevant
24668135 | Relationship of vitamin D, HIV, HIV treatment, and lipid levels in the Women's Interagency HIV Study of HIV-infected and uninfected women in the United States | J Int Assoc Provid AIDS Care | Schwartz, J. B.; Moore, K. L.; Yin, M.; Sharma, A.; Merenstein, D.; Islam, T.; Golub, E. T.; Tien, P. C.; Adeyemi, O. M. | Not relevant
19788344 | Retention and attendance of women enrolled in a large prospective study of HIV-1 in the United States | J Womens Health (Larchmt) | Hessol, N. A.; Weber, K. M.; Holman, S.; Robison, E.; Goparaju, L.; Alden, C. B.; Kono, N.; Watts, D. H.; Ameli, N. | Not relevant
23111572 | Risk factors for hospitalization and medical intensive care unit (MICU) admission among HIV-infected Veterans | J Acquir Immune Defic Syndr | Akgun, K. M.; Gordon, K.; Pisani, M.; Fried, T.; McGinnis, K. A.; Tate, J. P.; Butt, A. A.; Gibert, C. L.; Huang, L.; Rodriguez-Barradas, M. C.; Rimland, D.; Justice, A. C.; Crothers, K. | Not relevant
22589421 | Safety of varenicline among smokers enrolled in the lung HIV study | Nicotine Tob Res | Ferketich, A. K.; Diaz, P.; Browning, K. K.; Lu, B.; Koletar, S. L.; Reynolds, N. R.; Wewers, M. E. | Not relevant
22772666 | Semantic cueing improves category verbal fluency in persons living with HIV infection | J Neuropsychiatry Clin Neurosci | Iudicello, J. E.; Kellogg, E. J.; Weber, E.; Smith, C.; Grant, I.; Drane, D. L.; Woods, S. P. | Not relevant
23807068 | Sex disparities in overall burden of disease among HIV-infected individuals in the Veterans Affairs healthcare system | J Gen Intern Med | Blackstock, O. J.; Tate, J. P.; Akgun, K. M.; Crystal, S.; Duggal, M.; Edelman, E. J.; Gibert, C. L.; Gordon, K. S.; Rimland, D.; Rodriguez-Barradas, M. C.; Wang, E. A.; Fiellin, D. A.; Justice, A. C. | Not relevant
16080454 | Sexual behaviors and condom use of HIV-infected men and women of color attending a treatment and care clinic | J Natl Med Assoc | Absalon, J.; Della-Latta, P.; Wu, F.; El-Sadr, W. M. | Not relevant
18260803 | Sexually active HIV-positive patients frequently report never using condoms in audio computer-assisted self-interviews conducted at routine clinical visits | AIDS Patient Care STDS | Schackman, B. R.; Dastur, Z.; Ni, Q.; Callahan, M. A.; Berger, J.; Rubin, D. S. | Not relevant
19032064 | Short-term discontinuation of HAART regimens more common in vulnerable patient populations | AIDS Res Hum Retroviruses | Robison, L. S.; Westfall, A. O.; Mugavero, M. J.; Kempf, M. C.; Cole, S. R.; Allison, J. J.; Willig, J. H.; Raper, J. L.; Wilcox, C. M.; Saag, M. S. | Not relevant
22516847 | Short-term garlic supplementation and highly active antiretroviral treatment adherence, CD4+ cell counts, and human immunodeficiency virus viral load | Altern Ther Health Med | Liu, C.; Wang, C.; Robison, E.; Levine, A. M.; Gandhi, M.; Schwartz, R.; Weber, K. M.; Merenstein, D. | Not relevant
20724677 | Smoking-related health risks among persons with HIV in the Strategies for Management of Antiretroviral Therapy clinical trial | Am J Public Health | Lifson, A. R.; Neuhaus, J.; Arribas, J. R.; van den Berg-Wolf, M.; Labriola, A. M.; Read, T. R. | Not relevant
21692576 | Social context of rural Women with HIV/AIDS | Issues Ment Health Nurs | Phillips, K. D.; Moneyham, L.; Thomas, S. P.; Gunther, M.; Vyavaharkar, M. | Not relevant
20876195 | Spontaneous strategy use protects against visual working memory deficits in older adults infected with HIV | Arch Clin Neuropsychol | Woods, S. P.; Weber, E.; Cameron, M. V.; Dawson, M. S.; Delano-Wood, L.; Bondi, M. W.; Grant, I. | Not relevant
25375099 | Strong agreement of nationally recommended retention measures from the Institute of Medicine and Department of Health and Human Services | PLoS One | Rebeiro, P. F.; Horberg, M. A.; Gange, S. J.; Gebo, K. A.; Yehia, B. R.; Brooks, J. T.; Buchacz, K.; Silverberg, M. J.; Gill, J.; Moore, R. D.; Althoff, K. N. | Not relevant
25514125 | Structural and sociocultural factors associated with cervical cancer screening among HIV-infected African American women in Alabama | AIDS Patient Care STDS | Williams, M.; Moneyham, L.; Kempf, M. C.; Chamot, E.; Scarinci, I. | Not relevant
25397666 | Substance abuse, violence, and HIV/AIDS (SAVA) syndemic effects on viral suppression among HIV positive women of color | AIDS Patient Care STDS | Sullivan, K. A.; Messer, L. C.; Quinlivan, E. B. | Not relevant
23008124 | Substance use predictors of poor medication adherence: the role of substance use coping among HIV-infected patients in opioid dependence treatment | AIDS Behav | Gonzalez, A.; Mimiaga, M. J.; Israel, J.; Andres Bedoya, C.; Safren, S. A. | Not relevant
25719828 | Switch to maraviroc/raltegravir dual therapy leads to an unfavorable immune profile with low-level HIV viremia | Aids | Campillo-Gimenez, L. | Not relevant
21317595 | The impact of cocaine use on outcomes in HIV-infected patients receiving buprenorphine/naloxone | J Acquir Immune Defic Syndr | Sullivan, L. E.; Botsko, M.; Cunningham, C. O.; O'Connor, P. G.; Hersh, D.; Mitty, J.; Lum, P. J.; Schottenfeld, R. S.; Fiellin, D. A. | Not relevant
23756102 | The impact of neurobehavioral features on medication adherence in HIV: evidence from longitudinal models | AIDS Care | Panos, S. E.; Del Re, A. C.; Thames, A. D.; Arentsen, T. J.; Patel, S. M.; Castellon, S. A.; Singer, E. J.; Hinkin, C. H. | Not relevant
21262311 | The influence of human leukocyte antigen class I alleles and their population frequencies on human immunodeficiency virus type 1 control among African Americans | Hum Immunol | Lazaryan, A.; Song, W.; Lobashevsky, E.; Tang, J.; Shrestha, S.; Zhang, K.; McNicholl, J. M.; Gardner, L. I.; Wilson, C. M.; Klein, R. S.; Rompalo, A.; Mayer, K.; Sobel, J.; Kaslow, R. A. | Not relevant
19128527 | Timing is everything: antiretroviral nonadherence is associated with impairment in time-based prospective memory | J Int Neuropsychol Soc | Woods, S. P.; Dawson, M. S.; Weber, E.; Gibson, S.; Grant, I.; Atkinson, J. H. | Not relevant
19704170 | Transmitted antiretroviral drug resistance among acute and recent HIV infections in North Carolina from 1998 to 2007 | Antivir Ther | Hurt, C. B.; McCoy, S. I.; Kuruc, J.; Nelson, J. A.; Kerkau, M.; Fiscus, S.; McGee, K.; Sebastian, J.; Leone, P.; Pilcher, C.; Hicks, C.; Eron, J. | Not relevant
19845473 | Trends in multidrug treatment failure and subsequent mortality among antiretroviral therapy-experienced patients with HIV infection in North America | Clin Infect Dis | Deeks, S. G.; Gange, S. J.; Kitahata, M. M.; Saag, M. S.; Justice, A. C.; Hogg, R. S.; Eron, J. J.; Brooks, J. T.; Rourke, S. B.; Gill, M. J.; Bosch, R. J.; Benson, C. A.; Collier, A. C.; Martin, J. N.; Klein, M. B.; Jacobson, L. P.; Rodriguez, B.; Sterling, T. R.; Kirk, G. D.; Napravnik, S.; Rachlis, A. R.; Calzavara, L. M.; Horberg, M. A.; Silverberg, M. J.; Gebo, K. A.; Kushel, M. B.; Goedert, J. J.; McKaig, R. G.; Moore, R. D. | Not relevant
18420773 | Understanding hope in the face of an HIV diagnosis and high-risk behaviors | J Health Psychol | Harris, G. E.; Larsen, D. | Not relevant
20091340 | Work-related barriers and facilitators to antiretroviral therapy adherence in persons living with HIV infection | AIDS Behav | Torres-Madriz, G.; Lerner, D.; Ruthazer, R.; Rogers, W. H.; Wilson, I. B. | Not relevant
15741706 | A socioeconomic profile of older adults with HIV | Journal of Health Care for the Poor & Underserved | Joyce, G. F.; Goldman, D. P.; Liebowitz, A. A.; Alpert, A.; Bao, Y. | Not relevant
23799874 | Aging with HIV and disability: The role of uncertainty | AIDS Care | Solomon, Patricia; O'Brien, Kelly; Wilkins, Seanne; Gervais, Nicole | Not relevant
22380472 | Association between prescription cost sharing and adherence to initial combination antiretroviral therapy in commercially insured antiretroviral-naive patients with HIV | J Manag Care Pharm | Johnston, S. S.; Juday, T.; Seekins, D.; Espindle, D.; Chu, B. C. | Not relevant
17012091 | Body image in middle-aged HIV-infected and uninfected women | AIDS Care | Sharma, A.; Howard, A. A.; Schoenbaum, E. E.; Buono, D.; Webber, M. P. | Not relevant
16107946 | CD4 lymphocyte percentage predicts disease progression in HIV-infected patients initiating highly active antiretroviral therapy with CD4 lymphocyte counts >350 lymphocytes/mm3 | Journal of Infectious Diseases | Hulgan, T.; Raffanti, S.; Kheshti, A.; Blackwell, R. B.; Rebeiro, P. F.; Barkanic, G.; Ritz, B.; Sterling, T. R. | Not relevant
23927911 | Does Social Isolation Predict Hospitalization and Mortality Among HIV+ and Uninfected Older Veterans? | Journal of the American Geriatrics Society | Greysen, S. Ryan | Not relevant
17083502 | How do patients with HIV/AIDS understand and respond to health value questions? | J Gen Intern Med | Sherman, S. N.; Mrus, J. M.; Yi, M. S.; Feinberg, J.; Tsevat, J. | Not relevant
16971286 | Limitations in knowledge of HIV transmission among HIV-positive patients accessing case management services in a resource-poor setting | AIDS Care | Smith Fawzi, M. C.; Jagannathan, P.; Cabral, J.; Banares, R.; Salazar, J.; Farmer, P.; Behforouz, H. | Not relevant
25933048 | THE USE OF SELF-MANAGED TREATMENT STRATEGIES IN A PREDOMINANTLY LOW-INCOME, AFRICAN-AMERICAN SAMPLE OF WOMEN LIVING WITH HIV | Psychol Rep | Houston, E.; Osborn, A. | Not relevant
26044289 | Mortality Risk After AIDS-Defining Opportunistic Illness Among HIV-Infected Persons--San Francisco, 1981-2012 | J Infect Dis | Djawe, K. | Not relevant
25297848 | Spiritual coping predicts CD4-cell preservation and undetectable viral load over four years | AIDS Care | Kremer, H.; Ironson, G.; Kaplan, L.; Stuetzele, R.; Baker, N.; Fletcher, M. A. | Not relevant
25665886 | Successful coping in urban, community-dwelling older adults with HIV | J Assoc Nurses AIDS Care | DeGrezia, M. G. and Scrandis, D. | Not relevant
25767258 | Ten-year Survival by Race/Ethnicity and Sex Among Treated, HIV-infected Adults in the United States | Clin Infect Dis | Lesko, C. R. and Cole, S. R. and Miller, W. C. | Not relevant
24802222 | Complex lives: Resiliency of midlife African American women living with HIV/AIDS serving as informal kinship care providers | | Stokes, Charu | Not relevant
19609250 | Sexual and reproductive health of persons aged 10-24 years - United States, 2002-2007 | MMWR Surveill Summ | Gavin, L.; MacKay, A. P.; Brown, K.; Harrier, S.; Ventura, S. J.; Kann, L.; Rangel, M.; Berman, S.; Dittus, P.; Liddon, N.; Markowitz, L.; Sternberg, M.; Weinstock, H.; David-Ferdon, C.; Ryan, G. | Not relevant
109281199. Language: | Expanding the Health Action and Process Approach to Predict Physical Activity in African Americans With HIV/AIDS | Rehabilitation Counseling Bulletin | | Not relevant
103903736. Language: | Incidence of Antiretroviral Drug Interactions During Hospital Course: The Role of a Pharmacist-Led Antiretroviral Stewardship Program | Journal of Pharmacy Technology | Bias, Tiffany E.; Venugopalan, Veena; Berkowitz, Leonard B.; Cha, Agnes | Not relevant
20077319 | Menopause symptom attribution among midlife women in methadone treatment | Soc Work Health Care | Tuchman, E. | Not relevant
18484977 | Poor adherence to HIV monitoring and treatment guidelines for HIV-infected injection drug users | HIV Med | Wood, E.; Kerr, T.; Zhang, R.; Guillemi, S.; Palepu, A.; Hogg, R. S.; Montaner, J. S. | Not relevant
23315317 | Trends and disparities in antiretroviral therapy initiation and virologic suppression among newly treatment-eligible HIV-infected individuals in North America, 2001-2009 | Clin Infect Dis | Hanna, D. B.; Buchacz, K.; Gebo, K. A.; Hessol, N. A.; Horberg, M. A.; Jacobson, L. P.; Kirk, G. D.; Kitahata, M. M.; Korthuis, P. T.; Moore, R. D.; Napravnik, S.; Patel, P.; Silverberg, M. J.; Sterling, T. R.; Willig, J. H.; Lau, B.; Althoff, K. N.; Crane, H. M.; Collier, A. C.; Samji, H.; Thorne, J. E.; Gill, M. J.; Klein, M. B.; Martin, J. N.; Rodriguez, B.; Rourke, S. B.; Gange, S. J. | Not relevant
103157383. Language: | Knowledge, Self-efficacy, and Self-perceived Risk for Cardiovascular Disease among Asians Living With HIV: The Influence of HIV Stigma and Acculturation | JANAC: Journal of the Association of Nurses in AIDS Care | NA | Not relevant
19258590 | Pill taking from the perspective of HIV-Infected women who are vulnerable to antiretroviral treatment failure | Qual Health Res | Stevens, P. E.; Hildebrandt, E. | Not relevant
16505259 | Neutropenia in human immunodeficiency virus infection: data from the women's interagency HIV study | Arch Intern Med | Levine, A. M.; Karim, R.; Mack, W.; Gravink, D. J.; Anastos, K.; Young, M.; Cohen, M.; Newman, M.; Augenbraun, M.; Gange, S.; Watts, D. H. | Not relevant
21442499 | Differences in substance use and sexual partnering between men who have sex with men, men who have sex with men and women and transgender women | Cult Health Sex | Bowers, J. R.; Branson, C. M.; Fletcher, J.; Reback, C. J. | Not relevant
21153050 | Psychometric characteristics and race-related measurement invariance of stress and coping measures in adults with HIV/AIDS | AIDS Behav | Heckman, B. D.; Berlin, K. S.; Heckman, T. G.; Feaster, D. J. | Not relevant
22890224 | Electronic health information technology as a tool for improving quality of care and health outcomes for HIV/AIDS patients | Int J Med Inform | Virga, P. H.; Jin, B.; Thomas, J.; Virodov, S. | Not relevant
19307857 | Aging, neurocognition, and medication adherence in HIV infection | Am J Geriatr Psychiatry | Ettenhofer, M. L.; Hinkin, C. H.; Castellon, S. A.; Durvasula, R.; Ullman, J.; Lam, M.; Myers, H.; Wright, M. J.; Foley, J. | Not relevant
16511767 | Distribution of health care expenditures for HIV-infected patients | Clin Infect Dis | Chen, R. Y.; Accortt, N. A.; Westfall, A. O.; Mugavero, M. J.; Raper, J. L.; Cloud, G. A.; Stone, B. K.; Carter, J.; Call, S.; Pisu, M.; Allison, J.; Saag, M. S. | Not relevant
19197194 | Patterns of engagement in care by HIV-infected adults: South Carolina, 2004-2006 | Aids | Olatosi, B. A.; Probst, J. C.; Stoskopf, C. H.; Martin, A. B.; Duffus, W. A. | Not relevant
19537954 | Characteristics of HIV-positive cigarette smokers: a sample of smokers facing multiple challenges | AIDS Educ Prev | Humfleet, G. L.; Delucchi, K.; Kelley, K.; Hall, S. M.; Dilley, J.; Harrison, G. | Not relevant
19841589 | Inpatient health services utilization among HIV-infected adult patients in care 2002-2007 | J Acquir Immune Defic Syndr | Yehia, B. R.; Fleishman, J. A.; Hicks, P. L.; Ridore, M.; Moore, R. D.; Gebo, K. A. | Not relevant
25501613 | Proportions of patients with HIV retained in care and virally suppressed in New York City and the United States: higher than we thought | J Acquir Immune Defic Syndr | Xia, Q.; Kersanske, L. S.; Wiewel, E. W.; Braunstein, S. L.; Shepard, C. W.; Torian, L. V. | Not relevant
105305996. Language: | Health literacy in the context of HIV treatment: introducing the Brief Estimate of Health Knowledge and Action (BEHKA)---HIV version | AIDS & Behavior | Osborn, C. Y.; Davis, T. C.; Bailey, S. C.; Wolf, M. S. | Not relevant
25904747 | Decreased monocyte activation with daily acyclovir use in HIV-1/HSV-2 coinfected women | Sex Transm Infect | Redd, A. D. | Not relevant
25559604 | Impact of age on retention in care and viral suppression | J Acquir Immune Defic Syndr | Yehia, B. R.; Rebeiro, P.; Althoff, K. N.; Agwu, A. L.; Horberg, M. A.; Samji, H.; Napravnik, S.; Mayer, K.; Tedaldi, E.; Silverberg, M. J.; Thorne, J. E.; Burchell, A. N.; Rourke, S. B.; Rachlis, A.; Mayor, A.; Gill, M. J.; Zinski, A.; Ohl, M.; Anastos, K.; Abraham, A. G.; Kitahata, M. M.; Moore, R. D.; Gebo, K. A. | Not relevant
20976538 | The relative role of perceived partner risks in promoting condom use in a three-city sample of high-risk, low-income women | AIDS Behav | Ober, A. J.; Iguchi, M. Y.; Weiss, R. E.; Gorbach, P. M.; Heimer, R.; Ouellet, L. J.; Shoptaw, S.; Anglin, M. D.; Zule, W. A. | Not relevant
106274418. Language: | Informal social support for HIV medical care | Journal of HIV/AIDS & Social Services | Waddell, E. N.; Messeri, P. | Not relevant
26242055 | Late Diagnoses of HIV Infection in Mississippi: Implications for Improved Testing Strategies and Treatment | J Miss State Med Assoc | Johnson, K.; Dobbs, T. | Not relevant