# Appendix A Search Strategy

## PubMed Programs search 11/30/2015, updated 2/10/2016

((older or “middle age” or “middle aged” or “middle-age” or “middle-aged” or “Middle Aged”[Mesh] OR “Aged”[Mesh] or elderly or post-menopause or postmenopause or “Postmenopause”[Mesh])

AND (HIV or “HIV”[Mesh] or “Human immunodeficiency virus” or “HIV Infections”[Mesh] or (“Acquired Immunodeficiency Syndrome”) or “Acquired Immunodeficiency Syndrome”[Mesh])

AND (USA[Affiliation] or US or “United States” OR Alabama[Affiliation] OR AL[Affiliation] OR Alaska[Affiliation] OR AK[Affiliation] OR Arizona[Affiliation] OR AZ[Affiliation] OR Arkansas[Affiliation] OR AR[Affiliation] OR California[Affiliation] OR CA[Affiliation] OR Colorado[Affiliation] OR CO[Affiliation] OR Connecticut[Affiliation] OR CT[Affiliation] OR Delaware[Affiliation] OR “DE”[Affiliation] OR Florida[Affiliation] OR FL[Affiliation] OR Georgia[Affiliation] OR GA[Affiliation] OR Hawaii[Affiliation] OR HI[Affiliation] OR Idaho[Affiliation] OR ID[Affiliation] OR Illinois[Affiliation] OR IL[Affiliation] OR Indiana[Affiliation] OR Iowa[Affiliation] OR IA[Affiliation] OR Kansas[Affiliation] OR KS[Affiliation] OR Kentucky[Affiliation] OR KY[Affiliation] OR Louisiana[Affiliation] OR LA[Affiliation] OR Maine[Affiliation] OR ME[Affiliation] OR Maryland[Affiliation] OR MD[Affiliation] OR Massachusetts[Affiliation] OR MA[Affiliation] OR Michigan[Affiliation] OR MI[Affiliation] OR Minnesota[Affiliation] OR MN[Affiliation] OR Mississippi[Affiliation] OR MS[Affiliation] OR Missouri[Affiliation] OR MO[Affiliation] OR Montana[Affiliation] OR MT[Affiliation] OR Nebraska[Affiliation] OR NE[Affiliation] OR Nevada[Affiliation] OR NV[Affiliation] OR New Hampshire[Affiliation] OR NH[Affiliation] OR New Jersey[Affiliation] OR NJ[Affiliation] OR New Mexico[Affiliation] OR NM[Affiliation] OR New York[Affiliation] OR NY[Affiliation] OR North Carolina[Affiliation] OR NC[Affiliation] OR North Dakota[Affiliation] OR ND[Affiliation] OR Ohio[Affiliation] OR OH[Affiliation] OR Oklahoma[Affiliation] OR OK[Affiliation] OR Oregon[Affiliation] OR Pennsylvania[Affiliation] OR PA[Affiliation] OR Rhode Island[Affiliation] OR RI[Affiliation] OR South Carolina[Affiliation] OR SC[Affiliation] OR South Dakota[Affiliation] OR SD[Affiliation] OR Tennessee[Affiliation] OR TN[Affiliation] OR Texas[Affiliation] OR TX[Affiliation] OR Utah[Affiliation] OR UT Vermont[Affiliation] OR VT[Affiliation] OR Virginia[Affiliation] OR VA[Affiliation] OR Washington[Affiliation] OR WA[Affiliation] OR West Virginia[Affiliation] OR WV[Affiliation] OR Wisconsin[Affiliation] OR WI[Affiliation] OR Wyoming[Affiliation] OR WY[Affiliation] OR Puerto Rico[Affiliation] OR PR[Affiliation])

AND (women or female or “Women”[Mesh])

AND (program* OR treatment* OR intervention* or “Policy”[Mesh] or polic* or “Insurance”[Mesh] or insurance or “Government Agencies”[Mesh] or non-profit or “non profit” or nonprofit or “Organizations, Nonprofit”[Mesh] or “cascade of care”))

NOT (“Africa”[Mesh] OR (“addresses”[pt] or “autobiography”[pt] or “bibliography”[pt] or “biography”[pt] or “case reports”[pt] or “comment”[pt] or “congresses”[pt] or “dictionary”[pt] or “directory”[pt] or “editorial”[pt] or “festschrift”[pt] or “government publications”[pt] or “historical article”[pt] or “interview”[pt] or “lectures”[pt] or “legal cases”[pt] or “legislation”[pt] or “letter”[pt] or “news”[pt] or “newspaper article”[pt] or “patient education handout”[pt] or “periodical index”[pt] or “comment on” or review[tw] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] or cow[tw] or cows[tw] or chicken*[tw] or horse[tw] or horses[tw] or mice[tw] or mouse[tw] or bovine[tw] or sheep or ovine or murinae))

- Limit to Female
  Limit to 2005-
  Limit to humans
  Limit to English

## PubMed Comorbidities search 11/30/2016

((older or “middle age” or “middle aged” or “middle-age” or “middle-aged” or “Middle Aged”[Mesh] OR “Aged”[Mesh] or elderly or post-menopause or postmenopause or “Postmenopause”[Mesh])

AND (HIV or “HIV”[Mesh] or “Human immunodeficiency virus” or “HIV Infections”[Mesh] or (“Acquired Immunodeficiency Syndrome”) or “Acquired Immunodeficiency Syndrome”[Mesh])

AND (women or female or “Women”[Mesh])

AND (“Comorbidity”[Mesh] or comorbid*)

NOT (“Africa”[Mesh] OR (“addresses”[pt] or “autobiography”[pt] or “bibliography”[pt] or “biography”[pt] or “case reports”[pt] or “comment”[pt] or “congresses”[pt] or “dictionary”[pt] or “directory”[pt] or “editorial”[pt] or “festschrift”[pt] or “government publications”[pt] or “historical article”[pt] or “interview”[pt] or “lectures”[pt] or “legal cases”[pt] or “legislation”[pt] or “letter”[pt] or “news”[pt] or “newspaper article”[pt] or “patient education handout”[pt] or “periodical index”[pt] or “comment on” or review[tw] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] or cow[tw] or cows[tw] or chicken*[tw] or horse[tw] or horses[tw] or mice[tw] or mouse[tw] or bovine[tw] or sheep or ovine or murinae))

- Limit to Female
  Limit to 2005-
  Limit to humans
  Limit to English

## CINAHL, PsycINFO, SocINDEX program and comorbidity search 11/30/15, updated 2/10/2016

# | Query
S13 | S12
S12 | S10 NOT S11
S11 | (MH “Africa”)
S10 | S8 AND S9
S9 | (program* OR treatment* OR intervention* or Policy or policies or insurance or “Government Agencies” or non-profit or “non profit” or nonprofit or “cascade of care” or comorbid*)
S8 | S2 AND S4 AND S7
S7 | (MH “Women”) OR (women or female)
S6 | (MH “Women”)
S5 | ((MH “Human Immunodeficiency Virus+”) OR (MH “Acquired Immunodeficiency Syndrome”) OR (HIV or “Human immunodeficiency virus” or “Acquired Immunodeficiency Syndrome”)) AND (S2 AND S4)
S4 | ((MH “Human Immunodeficiency Virus+”) OR (MH “Acquired Immunodeficiency Syndrome”)) OR (HIV or “Human immunodeficiency virus” or “Acquired Immunodeficiency Syndrome”)
S3 | (MH “Human Immunodeficiency Virus+”) OR (MH “Acquired Immunodeficiency Syndrome”)
S2 | ((MH “Aged”) OR (MH “Gerontologic Care”) OR (MH “Middle Age”) OR (MH “Postmenopause”)) OR (older or “middle age” or “middle aged” or “middle-age” or “middle-aged” or elderly or post-menopause or postmenopause)
S1 | (MH “Aged”) OR (MH “Gerontologic Care”) OR (MH “Middle Age”) OR (MH “Postmenopause”)