# Summary and Implications

A number of MAT models of care have been developed and implemented in primary care settings. Key Informants noted that MAT models of care could be described using a framework focusing on the following four components: (1) pharmacological therapy; (2) psychosocial services; (3) integration of care; and (4) education and outreach. This report describes 12 representative/key models of care utilizing a framework based on these four components. Although other models of care have been developed, in many cases sources to understand their components could not be identified, or it was difficult to determine how they differed from the representative models. A challenge in understanding current MAT models of care is the limited published data on most models. No study has compared the effectiveness of one MAT model of care in primary care versus another; rather, most trials have focused on specific components, in particular which medication was used and the type of psychosocial services provided. However, the ideal model of care for a particular setting is likely to depend on a number of local factors, such as the expertise available, the population being served, proximity to an addiction center of excellence, reimbursement policies, geographic factors, and others. Several Key Informants noted that efforts to implement MAT have often failed due to poor reimbursement or because the model was financially unsustainable for other reasons. Therefore, decisions about MAT models of care may best be individualized to address the unique milieu of each implementation setting. In some situations, it may be appropriate to use elements of different models of care (e.g., implement nurse care manager-based coordination of care within a Hub and Spoke model of care) or to link models of care (e.g., ED or inpatient based screening and initiation of treatment linked with an office-based model of care for ongoing management).

Regarding the pharmacological therapy component, most MAT models of care in primary care settings to date have focused on provision of sublingual buprenorphine/naltrexone. Although implantable buprenorphine was approved by the FDA in 2016, research on its use in primary care settings is lacking. Similarly, although extended-release naltrexone has been shown to be effective in addiction treatment settings, research on its use in primary care settings is extremely sparse. Provision of additional pharmacological therapy choices for MAT has potential advantages in terms of expanding patient choices, reducing risk of diversion, and decreasing need for frequent followup in appropriate patients.

Key Informants consistently noted that the psychosocial services component is critical for any MAT model of care, but there is uncertainty about whether brief counseling (as required by DATA 2000) is sufficient, or whether more extensive psychosocial services should be routinely available. In addition, many different types of psychosocial services beyond brief counseling are available and it is uncertain which services should be prioritized when implementing a model of care. Although most evidence suggests that more intensive psychosocial services are not associated with superior outcomes to standard counseling, Key Informants noted that some patients require more intensive psychosocial services and that research is needed to identify higher-risk patients who would benefit from such services. Although Key Informants generally agreed that psychosocial services are best provided on-site, some models of care use services via an affiliated OTP or through telehealth/Web-based resources.

A core component of successful MAT models of care is the integration/coordination component, in order to manage issues related to OUD as well as psychological, medical, and primary care needs. Key Informants viewed successful integration of care as critical for the success of any MAT model of care. The MAT models of care that were viewed as particularly successful used a designated nonphysician staff member in the integration/coordination role, reducing the burden on the physician while increasing practice efficiency and permitting more patients to be effectively and safely treated.

Although the education and outreach component was not as well-defined in some models, this was viewed by Key Informants as critical for reducing stigma associated with MAT, increasing the pool of prescribing physicians, and increasing uptake, particularly in settings in which stigma is still high. Education was also viewed as critical for improving standards and quality of care. Our survey of MAT models of care indicated a number of approaches to education and outreach, including a Web-based learning network and educational resources, internet-based mentoring by more experienced physicians, meetings of community stakeholders, in-person educational sessions with patient and clinician educational sessions, and others.

Particular challenges in rural settings include a lack of waivered buprenorphine physicians, limited access to addiction expertise, persistent stigma associated with MAT, and long travel times for patients. Models of care developed in rural settings have attempted to address some of these issues by utilizing a Web-based learning network and accessing a national network of mentoring physicians. Other strategies that could be helpful include use of longer-acting medication formulations to reduce the number of followup visits in appropriate patients, use of telemedicine, engagement of community stakeholders, use of online interventions such as Web-based cognitive-behavioral therapy, and use of mid-level providers for administration of MAT.

We identified a number of important areas of uncertainty with regard to MAT models of care in primary care settings, including methods for measuring quality of care, how to assess patients to better individualize care, optimal psychosocial components of MAT, effectiveness of mid-level prescribing, enhancing access to and uptake of MAT in primary care settings, effectiveness of newer or alternative medications for OUD, optimal medications dosing strategies, cost and cost effectiveness, methods for reducing diversion, effective implementation methods, optimal methods for coordination and integration of care, and effectiveness of telehealth and telemedicine approaches. Research in these areas would be helpful for informing future efforts at dissemination and expansion of MAT in primary care settings. In the meantime, this technical brief describes a number of MAT models of care that have been developed and implemented in such settings, which may help inform further efforts at individualized implementation of MAT.