# References

1 Macrae J, Hyde P. (2015). HHS Launches Multi-pronged Effort to Combat Opioid Abuse.
2 American Psychiatric Association. (2013). The diagnostic and statistical manual of mental disorders: DSM-5.
3 Center for Behavioral Health Statistics and Quality. (2015). Behavioral Health Trends in the United States: Results from the 2014 National Survey on Drug Use and Health.
4 (2015). Overdose Death Rates.
5 Sullivan MD, Edlund MJ, Fan MY, et al. (2008). Trends in use of opioids for non-cancer pain conditions 2000–2005 in commercial and Medicaid insurance plans: the TROUP study. Pain.
6 Boudreau D, Von Korff M, Rutter CM, et al. (2009). Trends in long-term opioid therapy for chronic non-cancer pain. Pharmacoepidemiol Drug Saf.
7 Volkow ND. (2014). America’s Addiction to Opioids: Heroin and Prescription Drug Abuse.
8 Chou R, Deyo R, Devine B, et al. (2014). The Effectiveness and Risks of Long-Term Opioid Treatment of Chronic Pain.
9 Chou R, Turner JA, Devine EB, et al. (2015). The effectiveness and risks of long-term opioid therapy for chronic pain: a systematic review for a National Institutes of Health Pathways to Prevention Workshop. Ann Intern Med.
10 Cicero TJ, Ellis MS, Surratt HL, et al. (2014). The changing face of heroin use in the United States: a retrospective analysis of the past 50 years. JAMA Psychiatry.
11 Boscarino JA, Hoffman SN, Han JJ. (2015). Opioid-use disorder among patients on long-term opioid therapy: impact of final DSM-5 diagnostic criteria on prevalence and correlates. Subst Abuse Rehabil.
12 Behavioral Health Coordinating Committee Prescription Drug Abuse Subcommittee. (2013). Addressing Prescription Drug Abuse in the United States: Current Activities and Future Opportunities.
13 National Consensus Development Panel on Effective Medical Treatment of Opiate Addiction. (1998). Effective medical treatment of opiate addiction. JAMA.
14 Friedmann PD, Schwartz RP. (2012). Just call it “treatment”. Addiction Science & Clinical Practice.
15 Saitz R. (2015). Things that Work, Things that Don’t Work, and Things that Matter--Including Words. J Addict Med.
16 Department of Health and Human Services Substance Abuse and Mental Health Services Administration. (2016). Targeted Capacity Expansion: Medication Assisted Treatment - Prescription Drug and Opioid Addiction (Short Title - MAT-PDOA) Initial Announcement.
17 Mattick RP, Breen C, Kimber J, et al. (2014). Buprenorphine maintenance versus placebo or methadone maintenance for opioid dependence. Cochrane Database Syst Rev.
18 Mattick RP, Breen C, Kimber J, et al. (2009). Methadone maintenance therapy versus no opioid replacement therapy for opioid dependence. Cochrane Database Syst Rev.
19 National Institute on Drug Abuse. (2012). Medication-Assisted Treatment for Opioid Addiction.
20 Center for Substance Abuse Treatment. (2005). Medication-Assisted Treatment for Opioid Addiction in Opioid Treatment Programs.
21 The White House. (2015). Addressing Prescription Drug Abuse and Heroin Use [Presidential Memorandum].
22 Center for Substance Abuse Treatment. (2004). Clinical Guidelines for the Use of Buprenorphine in the Treatment of Opioid Addiction. Executive Summary.
23 Jones CM, Campopiano M, Baldwin G, et al. (2015). National and State Treatment Need and Capacity for Opioid Agonist Medication-Assisted Treatment. Am J Public Health.
24 Rosenblatt RA, Andrilla CH, Catlin M, et al. (2015). Geographic and specialty distribution of US physicians trained to treat opioid use disorder. Ann Fam Med.
25 Knudsen HK, Abraham AJ, Roman PM. (2011). Adoption and implementation of medications in addiction treatment programs. J Addict Med.
26 Egan JE, Casadonte P, Gartenmann T, et al. (2010). The Physician Clinical Support System-Buprenorphine (PCSS-B): a novel project to expand/improve buprenorphine treatment. J Gen Intern Med.
27 Providers’ Clinical Support System for Medication Assisted Treatment [PCSSMAT].
28 Substance Abuse and Mental Health Services Administration. Drug Addiction Treatment Act of 2000.
29 Chen H. (2014). Increasing Access to Opioid Addiction Treatment.
30 Patient-Centered Primary Care Collaborative. (2015). Vermont Hub and Spokes Health Homes Statewide.
31 Vermont Agency of Human Services. (2012). Integrated Treatment Continuum for Substance Use Dependence “Hub/Spoke” Initiative-Phase 1: Opioid Dependence.
32 Alliance of Community Health Plans. (2013). Vermont Health Homes for Opioid Addiction Hub & Spoke Program Overview.
33 Stoller K. (2015). Innovative Practices in Medication Assisted Treatment and Primary Care Coordination: Linking Buprenorphine Prescribers with Opioid Treatment Programs: Expand Capacity while Improving Quality.
34 Stoller K. (2015). A collaborative opioid prescribing (CoOP) model linking opioid treatment programs with office-based buprenorphine providers. Addict Sci Clin Pract.
35 Fiellin DA, Moore BA, Sullivan LE, et al. (2008). Long-term treatment with buprenorphine/naloxone in primary care: results at 2–5 years. Am J Addiction.
36 Fiellin DA, Pantalon MV, Chawarski MC, et al. (2006). Counseling plus buprenorphine-naloxone maintenance therapy for opioid dependence. N Engl J Med.
37 Fiellin DA, Pantalon MV, Pakes JP, et al. (2002). Treatment of heroin dependence with buprenorphine in primary care. Am J Drug Alcohol Abuse.
38 Alford DP, LaBelle CT, Kretsch N, et al. (2011). Collaborative care of opioid-addicted patients in primary care using buprenorphine: five-year experience. Arch Intern Med.
39 Alford DP, LaBelle CT, Richardson JM, et al. (2007). Treating homeless opioid dependent patients with buprenorphine in an office-based setting. J Gen Intern Med.
40 LaBelle CT, Han SC, Bergeron A, et al. (2016). Office-Based Opioid Treatment with Buprenorphine (OBOT-B): statewide implementation of the Massachusetts Collaborative Care Model in community health centers. J Subst Abuse Treat.
41 Altice FL, Bruce RD, Lucas GM, et al. (2011). HIV treatment outcomes among HIV-infected, opioid-dependent patients receiving buprenorphine/naloxone treatment within HIV clinical care settings: results from a multisite study. J Acquir Immune Defic Syndr.
42 Fiellin DA. (2010). Buprenorphine Treatment in HIV Primary Care: The HRSA SPNS BHIVES Initiative.
43 Fiellin DA, Weiss L, Botsko M, et al. (2011). Drug treatment outcomes among HIV-infected opioid-dependent patients receiving buprenorphine/naloxone. J Acquir Immune Defic Syndr.
44 Korthuis PT, Fiellin DA, Fu R, et al. (2011). Improving adherence to HIV quality of care indicators in persons with opioid dependence: the role of buprenorphine. J Acquir Immune Defic Syndr.
45 Korthuis PT, Tozzi MJ, Nandi V, et al. (2011). Improved quality of life for opioid-dependent patients receiving buprenorphine treatment in HIV clinics. J Acquir Immune Defic Syndr.
46 Lucas GM, Chaudhry A, Hsu J, et al. (2010). Clinic-based treatment of opioid-dependent HIV-infected patients versus referral to an opioid treatment program: A randomized trial. Ann Intern Med.
47 Raymond SC. (2012). Integrating Buprenorphine Opioid Abuse Treatment Into HIV Primary Care: Webinar Series.
48 Sullivan LE, Barry D, Moore BA, et al. (2006). A trial of integrated buprenorphine/naloxone and HIV clinical care. Clin Infect Dis.
49 TARGET Center. (2009). BEEHIVE Buprenorphine Program Tools.
50 Weiss L, Egan JE, Botsko M, et al. (2011). The BHIVES collaborative: organization and evaluation of a multisite demonstration of integrated buprenorphine/naloxone and HIV treatment. J Acquir Immune Defic Syndr.
51 Weiss L, Netherland J, Egan JE, et al. (2011). Integration of buprenorphine/naloxone treatment into HIV clinical care: lessons from the BHIVES collaborative. J Acquir Immune Defic Syndr.
52 HIV/AIDS Bureau Special Projects of National Significance Program. (2011). Integrating Buprenorphine Therapy Into HIV Primary Care Settings.
53 Thompson MA, Aberg JA, Hoy JF, et al. (2012). Antiretroviral treatment of adult HIV infection: 2012 recommendations of the International Antiviral Society-USA panel. JAMA.
54 Thompson MA, Mugavero MJ, Amico KR, et al. (2012). Guidelines for improving entry into and retention in care and antiretroviral adherence for persons with HIV: evidence-based recommendations from an International Association of Physicians in AIDS Care Panel. Ann Intern Med.
55 Komaromy M, Duhigg D, Metcalf A, et al. (2016). Project ECHO (Extension for Community Healthcare Outcomes): A new model for educating primary care providers about treatment of substance use disorders. Subst Abus.
56 Project ECHO. (2014). ECHO Access Opioid Use Disorder Treatment Guideline Opioid Abuse and Addiction Management Protocol.
57 Pupillo J. (2014). Project ECHO Trains, Empowers New Mexico FPs to Provide Subspecialty Care.
58 Mann C, Frieden T, Hyde PS, et al. (2014). Medication Assisted Treatment for Substance Use Disorders [Informational Bulletin].
59 Moses K, Klebonis J. (2015). Designing Medicaid Health Homes for Individuals with Opioid Dependency: Considerations for States [Brief].
60 Oregon Pain Guidance. (2016). Pain Management Guidance and Tools for Patients, Families, and Healthcare Professionals.
61 D’Onofrio G, O’Connor PG, Pantalon MV, et al. (2015). Emergency department-initiated buprenorphine/naloxone treatment for opioid dependence: a randomized clinical trial. JAMA.
62 Liebschutz JM, Crooks D, Herman D, et al. (2014). Buprenorphine treatment for hospitalized, opioid-dependent patients: a randomized clinical trial. JAMA Intern Med.
63 Pecoraro A, Ma M, Woody GE. (2012). The science and practice of medication-assisted treatments for opioid dependence. Subst Use Misuse.
64 Shanahan CW, Beers D, Alford DP, et al. (2010). A Transitional Opioid Program to Engage Hospitalized Drug Users. J Gen Intern Med.
65 Jones HE, Kaltenbach K, Heil SH, et al. (2010). Neonatal abstinence syndrome after methadone or buprenorphine exposure. N Engl J Med.
66 Jones HE, Johnson RE, Jasinski DR, et al. (2005). Buprenorphine versus methadone in the treatment of pregnant opioid-dependent patients: effects on the neonatal abstinence syndrome. Drug Alcohol Depend.
67 Conrad C, Bradley HM, Broz D, et al. (2015). Community Outbreak of HIV Infection Linked to Injection Drug Use of Oxymorhone -- Indiana 2015. MMWR Morb Mortal Wkly Rep.
68 LifeSpring Health Systems. About Us: Locations.
69 Chaudhry AA, Botsko M, Weiss L, et al. (2011). Participant characteristics and HIV risk behaviors among individuals entering integrated buprenorphine/naloxone and HIV care. J Acquir Immune Defic Syndr.
70 Cheever LW, Kresina TF, Cajina A, et al. (2011). A model federal collaborative to increase patient access to buprenorphine treatment in HIV primary care. J Acquir Immune Defic Syndr.
71 Egan JE, Netherland J, Gass J, et al. (2011). Patient perspectives on buprenorphine/naloxone treatment in the context of HIV care. J Acquir Immune Defic Syndr.
72 Finkelstein R, Netherland J, Sylla L, et al. (2011). Policy Implications of Integrating Buprenorphine/Naloxone Treatment and HIV Care. J Acquir Immune Defic Syndr.
73 Friedland G, Vlahov D. (2011). Integration of buprenorphine for substance-abuse treatment by HIV care providers. J Acquir Immune Defic Syndr.
74 Lum PJ, Little S, Botsko M, et al. (2011). Opioid-prescribing practices and provider confidence recognizing opioid analgesic abuse in HIV primary care settings. J Acquir Immune Defic Syndr.
75 Schackman BR, Leff JA, Botsko M, et al. (2011). The cost of integrated HIV care and buprenorphine/naloxone treatment: results of a cross-site evaluation. J Acquir Immune Defic Syndr.
76 Sullivan LE, Botsko M, Cunningham CO, et al. (2011). The impact of cocaine use on outcomes in HIV-infected patients receiving buprenorphine/naloxone. J Acquir Immune Defic Syndr.
77 Vergara-Rodriguez P, Tozzi MJ, Botsko M, et al. (2011). Hepatic safety and lack of antiretroviral interactions with buprenorphine/naloxone in HIV-infected opioid-dependent patients. J Acquir Immune Defic Syndr.
78 Executive Office of Health and Human Services (EOHHS). (2015). Get Help: Types of Treatment.
79 Haddad MS, Zelenev A, Altice FL. (2013). Integrating buprenorphine maintenance therapy into federally qualified health centers: real-world substance abuse treatment outcomes. Drug Alcohol Depend.
80 Westat, The AVISA Group. (2006). The SAMHSA Evaluation of the Impact of the DATA Waiver Program Summary Report.
81 SAMHSA: Substance Abuse and Mental Health Services Administration. (2015). Physician and Program Data.
82 Lines L. (2011). State-level influences on buprenorphine utilization: Variations in opioid addiction treatment.
83 Dick AW, Pacula RL, Gordon AJ, et al. (2015). Growth in nuprenorphine waivers for physicians increased potential access to opioid agonist treatment, 2002–11. Health Aff (Millwood).
84 Stein BD, Gordon AJ, Dick AW, et al. (2015). Supply of buprenorphine waivered physicians: the influence of state policies. J Subst Abuse Treat.
85 Stein BD, Pacula RL, Gordon AJ, et al. (2015). Where is buprenorphine dispensed to treat opioid use disorders? The role of private offices, opioid treatment programs, and substance abuse treatment facilities in urban and rural counties. Milbank Q.
86 Knudsen HK, Lofwall MR, Havens JR, et al. (2015). States’ implementation of the Affordable Care Act and the supply of physicians waivered to prescribe buprenorphine for opioid dependence. Drug Alcohol Depend.
87 Walley AY, Alperen JK, Cheng DM, et al. (2008). Office-based management of opioid dependence with buprenorphine: clinical practices and barriers. J Gen Intern Med.
88 Hutchinson E, Catlin M, Andrilla CH, et al. (2014). Barriers to primary care physicians prescribing buprenorphine. Ann Fam Med.
89 Sigmon SC. (2014). Access to treatment for opioid dependence in rural America: challenges and future directions. JAMA Psychiatry.
90 Molfenter T, Sherbeck C, Zehner M, et al. (2015). Implementing buprenorphine in addiction treatment: payer and provider perspectives in Ohio. Subst Abuse Treat Prev Policy.
91 DeFlavio JR, Rolin SA, Nordstrom BR, et al. (2015). Analysis of barriers to adoption of buprenorphine maintenance therapy by family physicians. Rural Remote Health.
92 Arfken CL, Johanson CE, di Menza S, et al. (2010). Expanding treatment capacity for opioid dependence with office-based treatment with buprenorphine: National surveys of physicians. J Subst Abuse Treat.
93 Providers’ Clinical Support System for Medication Assisted Treatment (PCSS MAT). PCSS MAT Training: How to prepare for a visit from the Drug Enforcement Agency (DEA) regarding buprenorphine prescribing.
94 Burns RM, Pacula RL, Bauhoff S, et al. (2016). Policies related to opioid agonist therapy for opioid use disorders: The evolution of state policies from 2004 to 2013. Subst Abus.
95 Amato L, Minozzi S, Davoli M, et al. (2011). Psychosocial combined with agonist maintenance treatments versus agonist maintenance treatments alone for treatment of opioid dependence. Cochrane Database Syst Rev.
96 Christensen DR, Landes RD, Jackson L, et al. (2014). Adding an Internet-delivered treatment to an efficacious treatment package for opioid dependence. J Consult Clin Psychol.
97 Fiellin DA, Barry DT, Sullivan LE, et al. (2013). A randomized trial of cognitive behavioral therapy in primary care-based buprenorphine. Am J Med.
98 Moore BA, Barry DT, Sullivan LE, et al. (2012). Counseling and directly observed medication for primary care buprenorphine maintenance: a pilot study. J Addict Med.
99 Galanter M, Dermatis H, Glickman L, et al. (2004). Network therapy: decreased secondary opioid use during buprenorphine maintenance. J Subst Abuse Treat.
100 Tetrault JM, Moore BA, Barry DT, et al. (2012). Brief versus extended counseling along with buprenorphine/naloxone for HIV-infected opioid dependent patients. J Subst Abuse Treat.
101 Weiss RD, Potter JS, Fiellin DA, et al. (2011). Adjunctive counseling during brief and extended buprenorphine-naloxone treatment for prescription opioid dependence: a 2-phase randomized controlled trial. Arch Gen Psychiatry.
102 Weiss RD, Potter JS, Griffin ML, et al. (2015). Long-term outcomes from the National Drug Abuse Treatment Clinical Trials Network Prescription Opioid Addiction Treatment Study. Drug Alcohol Depend.
103 Fudala PJ, Bridge TP, Herbert S, et al. (2003). Office-based treatment of opiate addiction with a sublingual-tablet formulation of buprenorphine and naloxone. N Engl J Med.
104 Lintzeris N, Ritter A, Panjari M, et al. (2004). Implementing buprenorphine treatment in community settings in Australia: experiences from the Buprenorphine Implementation Trial. Am J Addictions.
105 Rosenthal RN, Ling W, Casadonte P, et al. (2013). Buprenorphine implants for treatment of opioid dependence: randomized comparison to placebo and sublingual buprenorphine/naloxone. Addiction.
106 Ling W, Casadonte P, Bigelow G, et al. (2010). Buprenorphine implants for treatment of opioid dependence: a randomized controlled trial. JAMA.
107 Minozzi S, Amato L, Vecchi S, et al. (2011). Oral naltrexone maintenance treatment for opioid dependence. Cochrane Database Syst Rev.
108 Lobmaier P, Kornor H, Kunoe N, et al. (2008). Sustained-release naltrexone for opioid dependence. Cochrane Database Syst Rev.
109 Comer SD, Sullivan MA, Yu E, et al. (2006). Injectable, sustained-release naltrexone for the treatment of opioid dependence: a randomized, placebo-controlled trial. Arch Gen Psychiatry.
110 Larney S, Gowing L, Mattick RP, et al. (2014). A systematic review and meta-analysis of naltrexone implants for the treatment of opioid dependence. Drug Alcohol Rev.
111 Lobmaier PP, Kunoe N, Gossop M, et al. (2011). Naltrexone depot formulations for opioid and alcohol dependence: a systematic review. CNS Neurosci Ther.
112 Krupitsky E, Zvartau E, Blokhina E, et al. (2012). Randomized trial of long-acting sustained-release naltrexone implant vs oral naltrexone or placebo for preventing relapse to opioid dependence. Arch Gen Psychiatry.
113 Hulse GK, Morris N, Arnold-Reed D, et al. (2009). Improving clinical outcomes in treating heroin dependence: randomized, controlled trial of oral or implant naltrexone. Arch Gen Psychiatry.
114 Krupitsky E, Nunes EV, Ling W, et al. (2011). Injectable extended-release naltrexone for opioid dependence: a double-blind, placebo-controlled, multicentre randomised trial. Lancet.
115 Krupitsky E, Nunes EV, Ling W, et al. (2013). Injectable extended-release naltrexone (XR-NTX) for opioid dependence: long-term safety and effectiveness. Addiction.
116 Carrieri PM, Michel L, Lions C, et al. (2014). Methadone induction in primary care for opioid dependence: a pragmatic randomized trial (ANRS Methaville). PLoS ONE [Electronic Resource].
117 Roux P, Michel L, Cohen J, et al. (2012). Methadone induction in primary care (ANRS-Methaville): a phase III randomized intervention trial. BMC Public Health.
118 Fiellin DA, O’Connor PG, Chawarski M, et al. (2001). Methadone maintenance in primary care: a randomized controlled trial. JAMA.
119 King VL, Kidorf MS, Stoller KB, et al. (2006). A 12-month controlled trial of methadone medical maintenance integrated into an adaptive treatment model. J Subst Abuse Treat.
120 Ferri M, Minozzi S, Bo A, et al. (2013). Slow-release oral morphine as maintenance therapy for opioid dependence. Cochrane Database Syst Rev.
121 Minozzi S, Amato L, Bellisario C, et al. (2013). Maintenance agonist treatments for opiate-dependent pregnant women. Cochrane Database Syst Rev.
122 Woody GE, Poole SA, Subramaniam G, et al. (2008). Extended vs short-term buprenorphine-naloxone for treatment of opioid-addicted youth: a randomized trial. JAMA.
123 Gowing L, Farrell MF, Bornemann R, et al. (2011). Oral substitution treatment of injecting opioid users for prevention of HIV infection. Cochrane Database Syst Rev.
124 Chawarski MC, Mazlan M, Schottenfeld RS. (2008). Behavioral drug and HIV risk reduction counseling (BDRC) with abstinence-contingent take-home buprenorphine: a pilot randomized clinical trial. Drug Alcohol Depend.
125 Gossop M, Marsden J, Stewart D, et al. (2000). Patterns of improvement after methadone treatment: 1 year follow-up results from the National Treatment Outcome Research Study. Drug Alcohol Depend.
126 Nielsen S, Larance B, Degenhardt L, et al. (2016). Opioid agonist treatment for pharmaceutical opioid dependent people. Cochrane Database Syst Rev.
127 Minozzi S, Amato L, Davoli M. (2009). Maintenance treatments for opiate dependent adolescent. Cochrane Database Syst Rev.
128 Rahimi-Movaghar A, Amin-Esmaeili M, Hefazi M, et al. (2013). Pharmacological therapies for maintenance treatments of opium dependence. Cochrane Database Syst Rev.
129 McLellan AT, Starrels JL, Tai B, et al. (2014). Can Substance Use Disorders be Managed Using the Chronic Care Model? Review and Recommendations from a NIDA Consensus Group. Public Health Rev.
130 Bassuk EL, Hanson J, Greene RN, et al. (2016). Peer-Delivered Recovery Support Services for Addictions in the United States: A Systematic Review. J Subst Abuse Treat.
131 Carroll KM, Ball SA, Martino S, et al. (2008). Computer-assisted delivery of cognitive-behavioral therapy for addiction: a randomized trial of CBT4CBT. Am J Psychiatry.
132 Carroll KM, Ball SA, Martino S, et al. (2009). Enduring effects of a computer-assisted training program for cognitive behavioral therapy: a 6-month follow-up of CBT4CBT. Drug Alcohol Depend.
133 DiPaula BA, Menachery E. (2015). Physician-pharmacist collaborative care model for buprenorphine-maintained opioid-dependent patients. J Am Pharm Assoc.
134 Hersh D, Little SL, Gleghorn A. (2011). Integrating buprenorphine treatment into a public healthcare system: the San Francisco Department of Public Health’s office-based Buprenorphine Pilot Program. J Psychoactive Drugs.
135 Schmidt LA, Rieckmann T, Abraham A, et al. (2012). Advancing recovery: implementing evidence-based treatment for substance use disorders at the systems level. J Stud Alcohol Drugs.
136 Cottrill CB, Matson SC. (2014). Medication-assisted treatment of opioid use disorder in adolescents and young adults. Adolesc Med.
137 Alanis-Hirsch K, Croff R, Ford JH, et al. (2016). Extended-Release Naltrexone: A Qualitative Analysis of Barriers to Routine Use. J Subst Abuse Treat.
138 Alford DP, German JS, Samet JH, et al. (2016). Primary Care Patients with Drug Use Report Chronic Pain and Self-Medicate with Alcohol and Other Drugs. J Gen Intern Med.
139 Barry DT, Savant JD, Beitel M, et al. (2013). Pain and associated substance use among opioid dependent individuals seeking office-based treatment with buprenorphine-naloxone: a needs assessment study. Am J Addiction.
140 Cote J, Montgomery L. (2014). Sublingual buprenorphine as an analgesic in chronic pain: a systematic review. Pain Med.
141 Schackman BR, Leff JA, Polsky D, et al. (2012). Cost-effectiveness of long-term outpatient buprenorphine-naloxone treatment for opioid dependence in primary care. J Gen Intern Med.
142 Mohlman MK, Tanzman B, Finison K, et al. (2016). Impact of medication-assisted treatment for opioid addiction on Medicaid expenditures and health services utilization rates in Vermont. J Subst Abuse Treat.
143 Marsch LA, Guarino H, Acosta M, et al. (2014). Web-based behavioral treatment for substance use disorders as a partial replacement of standard methadone maintenance treatment. J Subst Abuse Treat.
144 Stein MD, Risi MM, Bailey GL, et al. (2016). Linkage to primary care for persons first receiving injectable naltrexone during inpatient opioid detoxification. J Subst Abuse Treat.
145 Salsitz EA, Joseph H, Frank B, et al. (2000). Methadone medical maintenance (MMM): treating chronic opioid dependence in private medical practice--a summary report (1983-1998). Mt Sinai J Med.
146 Merrill JO, Jackson TR, Schulman BA, et al. (2005). Methadone medical maintenance in primary care. An implementation evaluation. J Gen Intern Med.
147 Harris KA, Arnsten JH, Joseph H, et al. (2006). A 5-year evaluation of a methadone medical maintenance program. J Subst Abuse Treat.
148 National Institute on Drug Abuse. (2014). Principles of adolescent substance use disorder treatment: a research-based guide.
149 Wu L-T, Blazer DG, Li T-K, et al. (2011). Treatment use and barriers among adolescents with prescription opioid use disorders. Addict Behav.
150 Ober A, Watkins K, Hunter S, et al. (2015). An organizational readiness intervention and randomized controlled trial to test strategies for implementing substance use disorder treatment into primary care: SUMMIT study protocol.
151 Bogenschutz M. (2000). Comparing interventions for opioid dependent patients presenting in medical emergency departments. ClinicalTrials.gov.
152 Stein M. Linking opioid-dependent patients from inpatient detoxification to primary care.
153 Fox A. (2000). Buprenorphine group medical visits in primary care. ClinicalTrials.gov.
154 Sigmon S. (2015). Interim Buprenorphine: Leveraging Medication + Technology to Bridge Delays in Treatment Access.
155 Department of Health and Human Services. (2015). Funding Opportunity: Increasing Access to Medication-Assisted Treatment (MAT) in Rural Primary Care Practices (R18).
156 Watkins K. (2000). Integrated collaborative care for substance use disorders. ClinicalTrials.gov.